# Acknowledgements

The authors would like to thank Robert Kane, M.D., for overall guidance on the project, Mary Butler, Ph.D., for her project management expertise, and Marilyn Eells for outstanding editorial support of this Technical Brief.