# Summary and Implications

In addition to summarizing the available research on MPPs, this Technical Brief describes some of the key trends and challenges that have implications for the future of MPPs in the treatment of chronic noncancer pain. The most pressing problem facing the MPP, as we heard from our Key Informants, is the declining access to MPPs. Some of the reasons behind this decline are highlighted below. Another challenge discussed in this section is obtaining adequate reimbursement from third-party payers to providers of MPP treatment. Some of the controversies related to the role of opioids in the treatment of chronic pain are outlined because of both the prominence of the debate and the possible role of MPPs as an alternative to widespread opioid therapy. There is a short discussion of some patient concerns, which are, unfortunately, beyond the scope of the Brief. Finally, some research design challenges are highlighted.

## Decline in Access

Several factors have been implicated in the decline in the number of MPPs in the United States (the number in other countries may actually be growing32). Meldrum54 identified three dichotomies that have held the MPP back from being the “recognized standard of care in the United States”: (1) disciplinary collaboration in MPPs versus the “discipline-segmented organization of major medical centers,” (2) collaborative care in MPPs versus the fee-for-service model of healthcare payments, and (3) rehabilitative treatment in MPPs “focused on individualized assessment and patient behavior change” versus the curative medical model of treatment. In each of these dichotomies, the MPP model runs counter to the prevailing architecture of American healthcare financing and provision. Meldrum's first dichotomy draws attention to the requirement in an MPP of significant integration of care across several disciplines; major medical centers are aligned in silos by field and are increasingly competitive with each other for resources, including patients, floor plan, and research dollars. The second dichotomy points to the difficulty MPPs have getting adequate reimbursement for the time-intensive assessments and collaborative meetings needed to provide intensive multidisciplinary treatment. The pervasive fee-for-service model preferentially rewards percutaneous spinal procedures and spine surgery over assessments and behavioral therapy. Meldrum's third dichotomy is driven not just by healthcare payers and providers, but also by patients themselves. It is perhaps inevitable that a person in pain would seek a surgical cure or a pill over the intensive cognitive and behavioral changes required by an MPP.

Gatchel and his colleagues55 note the difficulty those involved with MPPs have faced trying to “sell” this treatment model to major stakeholders, including payers, legislators, etc. They posit that “many chronic pain clinicians were never trained in the requisite skills needed for dealing with the major forces/stakeholders…. [T]he vast majority of chronic pain practitioners have not yet developed the ‘political savvy’ to advocate for their patients and their profession.” They offer some suggestions for arguments in favor of their model, including the “serious bioethical issue” when third-party payers refuse to cover MPP treatment or carve out portions of the model (see below), “seriously compromis[ing] the integrity and effectiveness” of the treatment and raising “significant medicolegal and ethical concerns.”

The medical director of large insurance company Aetna, Dr. Jeff Livovich, has stated that MPPs have not done enough to make payers aware of the benefits of their programs, in efficacy and cost-effectiveness. “My perception is that third-party payors could benefit from a greater understanding of what interdisciplinary care is about…. For now, when people think of pain medicine they think of interventional techniques.”56,v

v The original used the acronym “IPRPs”—interdisciplinary pain rehabilitation programs—another name for MPPs.

## Carve-Outs and Third-Party Payment Issues

Gatchel and colleagues55 provide a succinct explanation of the issue of carve-outs in third-party reimbursement policies.

[I]nstead of authorizing full multidisciplinary pain management programs, MCOs [Managed Care Organizations] have been “carving out” portions of comprehensive, integrated programs (i.e., sending patients to different providers for their various needs outside of the comprehensive pain management programs), thus diluting the proven successful outcomes of such integrated programs in an effort to cut costs.40,57,58 While MCOs may be most guilty of compromising the integrity of chronic pain management services, it is important to note that all health-insurance carriers manage health care to a certain degree, and accordingly share in the responsibility for the provision of suboptimal care. They lose sight of the fact that, in the long run, multidisciplinary programs that help chronic pain patients resume productive lives produce much greater long-term cost-effectiveness in terms of future health care, tax, legal, and general economic factors.

Schatman32 challenges the efficiency of carve-outs by referring readers to Gatchel's work on the topic and to note that the practice has “paradoxically produced the effect of steering patients away from multidisciplinary treatments that demonstrably reduce health-care utilization, and toward more extensive unimodal therapies associated with poorer outcomes.”55

According to the experts we consulted, the treatments most likely to be carved out from an MPP are physical therapy and psychological/behavioral treatments. Managed care organizations may have preferred networks of providers for these services to which they direct their beneficiaries—particularly since both PT and psychological treatments are generally pursued during repeated visits over long periods of time.

In the context of Workers' Compensation insurance, there may also be a need to document that psychological treatment provided in an MPP to address issues caused by the workplace incident alone, rather than pre-existing conditions that would not be covered.

## Role of Opioids

There is no consensus among MPP providers on the appropriate role of long-term opioid therapy for people with chronic pain. Many of the included studies noted a policy of tapering patients off opioids when (or before) they begin treatment (see Table D-2 in Appendix D for examples under “medical component”). Other practitioners believe well-managed opioid therapy can improve quality of life for some patients with chronic pain.59,60 An in-depth review of the benefits and costs—both economic and otherwise—of use of opioids to treat chronic, noncancer pain is beyond the scope of this work. In brief, the key issues are as follows:

- Efficacy. The use of opioids to manage acute pain and cancer pain is widespread and relatively straightforward, but their appropriateness for chronic pain is sometimes disputed.61
- Side effects. Dry mouth, constipation, and nausea are among the most common adverse effects of opioid therapy; a substantial minority of participants in RCTs of opioids for chronic noncancer pain withdrew from the trials because of adverse effects (20-30 percent for opioids versus 5 to 15 percent for placebo).61
- Tolerance, dose escalation, and induced hyperalgesia. Some patients on long-term opioid therapy receive increasing doses of their medication over time. There are several potential causes: it may reflect an increase in pain due to progression of the underlying disease; development of a tolerance to opioids; or development of opioid-induced hyperalgesia (increased pain sensitivity). In some cases, dose escalation may be an indication of addiction or “diversion” of the drug (e.g., selling or giving drugs to others). 61 However, most studies suggest fewer than 1 in 5 patients taking opioids for chronic noncancer pain become addicted.61,62
- Misuse and abuse potential. National surveys suggest that more than 19 million Americans misuse opioids, with more than 2 million “new initiates” to prescription opioid misuse every year.63 People who misuse these drugs may feel they are safer and more pure than street drugs—and more easily available.64 However, unmonitored use of opioids can be dangerous: accidental overdose of opioids caused 11,499 deaths in the US in 2007, up from around 3000 in 1999.^65^
- Accessibility and regulations. Because of the potential for abuse, opioids are strictly regulated at both a federal and a state level. These regulations can make it more difficult for patients to receive appropriate opioid treatment. Passik66 notes that “[p]hysicians who prescribe opioids must maintain extensive documentation and may be subject to investigation by the Drug Enforcement Administration.”67-69 Patients may have difficulty finding an accessible pharmacy willing to stock some types of opioids.70
- The FDA is currently developing risk evaluation and mitigation strategies (REMS) to reduce misuse of opioids.71 Some believe this intervention may have the effect of reducing patient access to these drugs in the future; however, the policies are still being developed, so their impact is not yet clear.64

The potential harm from misuse of opioids must be weighed against a humane concern for the suffering of people with persistent pain. This has not been an easy balance to find. Solutions will likely require education of both physicians and patients on appropriate use of opioids, research to identify the patients most likely to benefit from opioid therapy, and improved access to non-drug therapies like MPPs that could reduce the need for opioids.

## Patient-Related Issues

A simplistic reading of the biopsychosocial model of pain may lead to the unfortunate (and inaccurate) implication that the continued pain is somehow the patient's fault. In physician language about a patient's history of treatment, the stock phrase is that the “patient failed” X or Y treatment. Surgeons may refer to an unsuccessfully operated patient as a “failed back” (of this tendency to reduce patients to their problems, one chronic pain patient noted, “It had always seemed that I, as a person, was just along as transportation for whatever body part was the focus of the appointment that day”72). Patients may feel that the frustrated physicians treating them under the curative model feel that they are malingering or purposely exaggerating their symptoms. Lebovits addresses the difficult interaction between psychology and pain, noting that it can be difficult to tell which came first, and that the two can interact to the patient's detriment.

Individuals experiencing chronic pain can also exhibit significant psychopathology that might have existed premorbidly but also may be reactive to pain and/or the lack of relief and exacerbated by iatrogenic or traumatic injuries…. The result of this concurrent psychopathology is that the patient's pain might not be taken seriously enough. The patient might be dismissed as “crazy” and their pain as “in their head,” which might result in not being treated at all or not being treated medically, just psychiatrically. Alternatively, they might be treated overly aggressively medically in that their depression or somatization disorder might just amplify their pain or their suffering or illness behavior.73

At least historically, some physicians have believed that pain with a psychological component is in the patient's control. As quoted in Meldrum,74 William Livingston, a surgeon in Oregon (1892-1966), “fiercely refused to ‘deny such cases an organic basis and to ascribe the symptoms to psychic causes for which the patient may be responsible.’”75

A more accurate description of the psychosocial factors in the biopsychosocial model of pain is as part of a complex system in which there is “a dynamic and reciprocal interplay among biological, psychological, and sociocultural factors that shapes the experience and responses of patients.”76,77

## Study Design

The literature includes relatively few RCTs. Several authors noted ethical issues prevented them from using random assignment to treatment (see examples78-82). The studies which did randomize participants were nearly all based in Europe (only three were based in the United States and three in Australia).

The comparison/control groups in the nonrandomized studies were often convenience samples—for example, of those who dropped out of treatment or who were accepted to the program, but never began treatment—and likely to introduce bias. Waiting list controls in programs with capacity constraints may be the best solution when randomization is not feasible.

Not all researchers in the field believe that randomization to treatment protocols is ideal. For example, Currie and colleagues,17 among others, note that an RCT design is “neither feasible nor desired” for their needs. They are concerned about the likely exclusion from randomized trials of patients with the typically complicated clinical profile of comorbidities and long treatment histories, as well as the potential bias associated with relying on patients volunteering for randomization.

Another possible source of bias is the outcome assessments, which are frequently completed by the treatment team or another nonblinded person. A few studies did use blinded assessors (examples83-86). High attrition, especially over the long-term followup periods may also bias outcome assessments.

A more difficult issue to control is referral bias. As noted, MPPs are often seen as the last resort for patients whose pain has not responded to multiple prior treatments. These patients may not be representative of the larger chronic pain population; for example, they may be unusually persistent to have continued to seek treatment after multiple failed attempts to cure their pain. Turk and Rudy44 considered several aspects of referral bias, noting that epidemiological studies have found that specialty pain clinic patients show signs of greater emotional function impairments compared to chronic pain sufferers in the community or being treated in general practice. Generally, Turk and Rudy note that patients seen in pain clinics tend to be more difficult to treat than the general pain population.

An ongoing U.S. RCT by Gatchel et al.87 compares random assignment of MPP treatment to usual care (“standard anesthesia pain clinic medical care”) in 66 active-duty military personnel matched on age, gender, race, and time since onset. Because their subjects are in the military and were selected to have at least 18 months remaining in their service obligation, the researchers were able to obtain 100 percent followup over a relatively long period. This study overcomes some of the design difficulties others have faced; however, it may be of limited applicability to the civilian population (and indeed was meant to specifically address “the enormous costs associated with chronic musculoskeletal conditions within the U.S. Armed Forces”).

In practice, finding appropriate control groups for studies of patients with chronic pain is problematic. As noted above (“study design”), several researchers have identified ethical issues with waiting list controls. Avoiding selection bias is difficult without a centralized health system that catalogs all patients experiencing chronic pain. The diversity among third-party payers' reimbursement policies for MPP treatment further complicates selection issues. As a result, most U.S. studies are essentially convenience samples of patients referred to the clinic, accepted for treatment, and approved for reimbursement.