# References

1 Scascighini L, Toma V, Dober-Spielmann S, et al. Multidisciplinary treatment for chronic pain: a systematic review of interventions and outcomes. Rheumatology. May. 2008;47(5):670-8. [pmid: 18375406].
2 Gatchel RJ, Okifuji A. Evidence-based scientific data documenting the treatment and cost-effectiveness of comprehensive pain programs for chronic nonmalignant pain. Journal of Pain. Nov. 2006;7(11):779-93. [pmid: 17074616].
3 American Pain Society. Remove barriers to interdisciplinary pain care approaches. Available at: http://www.ampainsoc.org/advocacy/legislative_agenda.htm. March 29, 2010.
4 International Association for the Study of Pain. Pain, IASP Pain Terminology. http://www.iasp-pain.org/AM/Template.cfm?Section=Pain_Definitions&Template=/CM/HTMLDisplay. cfm&ContentID=1728#Pain. 1994.
5 Turk DC, Okifuji A. Pain Terms and Taxonomies of Pain. Loeser JD, editor. Bonica's Management of Pain. 3rd ed. Philadelphia. Lippincott Williams & Wilkins. 2001:17-25.
6 Sanders SH, Harden RN, Vicente PJ. Evidence-based clinical practice guidelines for interdisciplinary rehabilitation of chronic nonmalignant pain syndrome patients. Pain Pract. Dec. 1. 2005;5(4):303-15. [pmid: 17177763].
7 Young Casey C, Greenberg MA, Nicassio PM, et al. Transition from acute to chronic pain and disability: a model including cognitive, affective, and trauma factors. Pain. Jan. 2008;134(1-2):69-79. [pmid: 17504729].
8 Gatchel RJ, Epker J. Psychosocial Predictors of Chronic Pain and Response to Treatment. Gatchel RJ, Turk DC, editors. Psychosocial Factors in Pain. New York. The Guilford Press. 1999:412-34.
9 Von Korff M. Perspectives on management of back pain in primary care. Gebhart GL, Hammond DL, Jensen TS, editors. Proceedings of the Seventh World Congress on Pain: Vol 2. Progress in pain research and management. Seattle, WA. IASP Press. 1994:97-110.
10 Linton SJ. Prevention with Special Reference to Chronic Musculoskeletal Disorders. Gatchel RJ, Turk DC, editors. Psychosocial Factors in Pain: Critical Perspectives. New York. The Guilford Press. 1999:374-89.
11 Mayer TG, Gatchel RJ. Functional restoration for spinal disorders: The sports medicine approach. Philadelphia. Lea & Febiger. 1988.
12 Garofalo JP, Polatin P. Low Back Pain: An Epidemic in Industrialized Countries. Gatchel RJ, Turk DC, editors. Psychosocial Factors in Pain: Critical Perspectives. New York. The Guilford Press. 1999:164-74.
13 Mayer TG. Rationale for modern spinal care. Mayer TG, Mooney V, Gatchel RJ, editors. Contemporary conservative care for painful spinal disorders. Philadelphia. Lea & Febiger. 1991:3-9.
14 Turk DC, Okifuji A, Sinclair JD, et al. Interdisciplinary treatment for fibromyalgia syndrome: clinical and statistical significance. Arthritis Care & Research. Jun. 1998;11(3):186-95. [pmid: 9782810].
15 Gustafsson M, Ekholm J, Broman L. Effects of a multiprofessional rehabilitation programme for patients with fibromyalgia syndrome. Journal of Rehabilitation Medicine. May. 2002;34(3):119-27. [pmid: 12395939].
16 Jensen MP, Nielson WR, Turner JA, et al. Readiness to self-manage pain is associated with coping and with psychological and physical functioning among patients with chronic pain. Pain. Aug. 2003;104(3):529-37. [pmid: 12927625].
17 Currie SR, Hodgins DC, Crabtree A, et al. Outcome from integrated pain management treatment for recovering substance abusers. Journal of Pain. Mar. 2003;4(2):91-100. [pmid: 14622720].
18 Cedraschi C, Desmeules J, Rapiti E, et al. Fibromyalgia: a randomised, controlled trial of a treatment programme based on self management. Annals of the Rheumatic Diseases. Mar. 2004;63(3):290-6. [pmid: 14962965].
19 Jensen MP, Nielson WR, Turner JA, et al. Changes in readiness to self-manage pain are associated with improvement in multidisciplinary pain treatment and pain coping. Pain. Sep. 2004;111(1-2):84-95. [pmid: 15327812].
20 Angst F, Brioschi R, Main CJ, et al. Interdisciplinary rehabilitation in fibromyalgia and chronic back pain: a prospective outcome study. Journal of Pain. Nov. 2006;7(11):807-15. [pmid: 17074622].
21 Hooten WM, Townsend CO, Sletten CD, et al. Treatment outcomes after multidisciplinary pain rehabilitation with analgesic medication withdrawal for patients with fibromyalgia. Pain Medicine. Jan-Feb. 2007;8(1):8-16. [pmid: 17244099].
22 Suman AL, Biagi B, Biasi G, et al. One-year efficacy of a 3-week intensive multidisciplinary non-pharmacological treatment program for fibromyalgia patients. Clinical & Experimental Rheumatology. Jan-Feb. 2009;27(1):7-14. [pmid: 19327223].
23 Angst F, Verra ML, Lehmann S, et al. Clinical effectiveness of an interdisciplinary pain management programme compared with standard inpatient rehabilitation in chronic pain: a naturalistic, prospective controlled cohort study. Journal of Rehabilitation Medicine. Jun. 2009;41(7):569-75. [pmid: 19543669].
24 Verra ML, Angst F, Brioschi R, et al. Does classification of persons with fibromyalgia into Multidimensional Pain Inventory subgroups detect differences in outcome after a standard chronic pain management program?. Pain Research & Management. Nov-Dec. 2009;14(6):445-53. [pmid: 20011715].
25 Burnham R, Day J, Dudley W. Multidisciplinary chronic pain management in a rural Canadian setting. Canadian Journal of Rural Medicine. 2010;15(1):7-13. [pmid: 20070924].
26 Moore JE, Armentrout DP, Parker JC, et al. Empirically derived pain-patient MMPI subgroups: prediction of treatment outcome. Journal of Behavioral Medicine. Feb. 1986;9(1):51-63. [pmid: 3701859].
27 Scharff L, Marcus DA. Interdisciplinary outpatient group treatment of intractable headache. Headache. Feb. 1994;34(2):73-8. [pmid: 8163369].
28 Sanders SH, Brena SF. Empirically derived chronic pain patient subgroups: the utility of multidimensional clustering to identify differential treatment effects. Pain. Jul. 1993;54(1):51-6. [pmid: 8378103].
29 Magnusson JE, Riess CM, Becker WJ. Effectiveness of a multidisciplinary treatment program for chronic daily headache. Canadian Journal of Neurological Sciences. Feb. 2004;31(1):72-9. [pmid: 15038474].
30 Gunreben-Stempfle B, Griessinger N, Lang E, et al. Effectiveness of an intensive multidisciplinary headache treatment program. Headache. Jul. 2009;49(7):990-1000. [pmid: 19473281].
31 Skouen JS, Grasdal A, Haldorsen EMH. Return to work after comparing outpatient multidisciplinary treatment programs versus treatment in general practice for patients with chronic widespread pain. European Journal of Pain: Ejp. Feb. 2006;10(2):145-52.
32 Schatman ME. Interdisciplinary chronic pain management: perspectives on history, current status, and future viability. Fishman SM, Ballantyne J, Rathmell J, editors. Bonica's Management of Pain. 4 ed. Baltimore, MD. Lippincott Williams & Wilkins. 2010:1523-32.
33 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. 2002;31(1):115-23. [pmid: 11914306].
34 American Academy of Pain Management. AAPM - Pain Program Accreditation. Available at: http://www.aapainmanage.org/programs/PPAMain.php. August 26, 2010.
35 CARF. Find an Accredited Provider. Available at: http://www.carf.org/providerSearch.aspx. August 26, 2010.
36 Turk DC, Okifuji A. Treatment of Chronic Pain Patients: Clinical Outcomes, Cost-Effectiveness, and Cost-Benefits of Multidisciplinary Pain Centers. Critical Reviews in Physical and Rehabilitation Medicine. 1998;10(2):181-208.
37 Gatchel RJ, Turk DC. Interdisciplinary Treatment of Chronic Pain Patients. Gatchel RJ, Turk DC, editors. Psychosocial Factors in Pain. New York. The Guilford Press. 1999:435-44.
38 Loeser JD, Egan KJ. Inpatient Pain Treatment Program. Loeser JD, Egan KJ, editors. Managing the chronic pain patient: theory and practice at the University of Washington Multidisciplinary Pain Center. New York. Raven Press. 1989:37-49.
39 Turk DC, Stacey BR. Multidisciplinary Pain Centers Treatment of Chronic Back Pain. Frymoyer JW, editor. The Adult Spine: Principles and Practice. 2d ed. Philadelphia. Lippincott-Raven Publishers. 1997;1:253-74.
40 Robbins H, Gatchel RJ, Noe C, et al. A prospective one-year outcome study of interdisciplinary chronic pain management: compromising its efficacy by managed care policies. Anesthesia & Analgesia. Jul. 2003;97(1):156-62. [pmid: 12818959].
41 Stanos S, Houle TT. Multidisciplinary and interdisciplinary management of chronic pain. Physical Medicine & Rehabilitation Clinics of North America. May. 2006;17(2):435-50. [pmid: 16616276].
42 Masuda A, Koga Y, Hattanmaru M, et al. The effects of repeated thermal therapy for patients with chronic pain. Psychotherapy & Psychosomatics. 2005;74(5):288-94. [pmid: 16088266].
43 Turk DC, Swanson K. Efficacy and Cost-Effectiveness Treatment for Chronic Pain: An Analysis and Evidence-Based Synthesis. Schatman ME, Campbell A, editors. Chronic pain management: guidelines for multidisciplinary program development. New York. Informa Healthcare USA. 2007:15-38.
44 Turk DC, Rudy TE. Neglected factors in chronic pain treatment outcome studies--referral patterns, failure to enter treatment, and attrition. Pain. Oct. 1990;43(1):7-25. [pmid: 2277718].
45 Bendix AF, Bendix T, Vaegter K, et al. Multidisciplinary intensive treatment for chronic low back pain: a randomized, prospective study. Cleveland Clinic Journal of Medicine. Jan-Feb. 1996;63(1):62-9. [pmid: 8590519].
46 Mayer TG, Gatchel RJ, Kishino N, et al. Objective assessment of spine function following industrial injury. A prospective study with comparison group and one-year follow-up. Spine. Jan. 1. 1985;10(6):482-93. [pmid: 2934829].
47 Crown S. Psychological aspects of low back pain. Rheumatol Rehabil. May. 1. 1978;17(2):114-24. [pmid: 149356].
48 Wang H, Schiltenwolf M, Buchner M. The role of TNF-alpha in patients with chronic low back pain-a prospective comparative longitudinal study. Clinical Journal of Pain. Mar-Apr. 2008;24(3):273-8. [pmid: 18287835].
49 Lipchik GL, Milles K, Covington EC. The effects of multidisciplinary pain management treatment on locus of control and pain beliefs in chronic non-terminal pain. Clinical Journal of Pain. Mar. 1993;9(1):49-57. [pmid: 8477140].
50 Williams ACdC, Nicholas MK, Richardson PH, et al. Generalizing from a controlled trial: the effects of patient preference versus randomization on the outcome of inpatient versus outpatient chronic pain management. Pain. Oct. 1999;83(1):57-65. [pmid: 10506672].
51 Chapman SL, Jamison RN, Sanders SH, et al. Perceived treatment helpfulness and cost in chronic pain rehabilitation. Clinical Journal of Pain. Jun. 2000;16(2):169-77. [pmid: 10870730].
52 Boothby JL, Thorn BE, Stroud MW, et al. Coping with Pain. Gatchel RJ, Turk DC, editors. Psychosocial Factors in Pain. New York. The Guilford Press. 1999:343-59.
53 Turk DC, Dworkin RH, Allen RR, et al. Core outcome domains for chronic pain clinical trials: IMMPACT recommendations. Pain. Dec. 1. 2003;106(3):337-45. [pmid: 14659516].
54 Meldrum ML. Brief History of Multidisciplinary Management of Chronic Pain, 1900-2000. Schatman ME, Campbell A, editors. Chronic pain management: guidelines for multidisciplinary program development. New York. Informa Healthcare USA. 2007:1-13.
55 Gatchel RJ, Kishino ND, Noe C. “Carving-Out” Services from Multidisciplinary Chronic Pain Management Programs: Negative Impact on Therapeutic Efficacy. Schatman ME, Campbell A, editors. Chronic pain management: guidelines for multidisciplinary program development. New York. Informa Healthcare USA. 2007:39-48.
56 Martinsons J. Financial Rehab for Interdisciplinary Programs. APS Bulletin. 2007;17(3). np.
57 Gatchel RJ, Noe C, Gajraj N, et al. The negative impact on an interdisciplinary pain management program of insurance “treatment carve out” practices. J Work Compens. 2001;10:50-63.
58 Keel P, Wittig R, Deutschman R, et al. Effectiveness of in-patient rehabilitation for sub-chronic and chronic low back pain by an integrative group treatment program. Scand J Rehabil Med. 1998;30:211-9. [pmid: 9825385].
59 Portenoy RK. Opioid therapy for chronic nonmalignant pain: a review of the critical issues. J Pain Symptom Manage. 1996;11(4):203-17. [pmid: 8869456].
60 Ballantyne J. Problems with Chronic Opioid Therapy and Need for a Multidisciplinary Approach. Schatman ME, Campbell A, editors. Chronic pain management: guidelines for multidisciplinary program development. New York. Informa Healthcare USA. 2007:49-61.
61 Goucke CR, Visser EJ. Opioids and chronic noncancer pain. Wilson PR, Watson PJ, Haythornthwaite JA, et al., editors. Clinical Pain Management: Chronic Pain. 2d ed. London. Hodder and Stoughton Limited. 2008:207-29.
62 Fishbain DA, Rosomoff HL, Rosomoff RS. Drug abuse, dependence, and addiction in chronic pain patients. Clinical Journal of Pain. Jun. 1992;8(2):77-85. [pmid: 1633386].
63 Denisco R. Prescription Opioid Abuse: Public Health Perspective. Paper presented at: IMMPACT-X. 2009. Arlington, VA. Available at: http://www.immpact.org/meetings/Immpact10/background/Denisco.pdf.
64 Ballantyne J. U.S. Opioid Risk Mangement Initiatives. Pain Clinical Updates. Nov. 2009;17(6):1-5.
65 Okie S. A flood of opioids, a rising tide of deaths. N Engl J Med. Nov. 18. 2010;363(21):1981-5. [pmid: 21083382].
66 Passik SD. Issues in long-term opioid therapy: unmet needs, risks, and solutions. Mayo Clinic Proceedings. Jul. 2009;84(7):593-601. [pmid: 19567713].
67 Gourlay DL, Heit HA, Almahrezi A. Universal precautions in pain medicine: a rational approach to the treatment of chronic pain. Pain Med. Jan. 1. 2005;6(2):107-12. [pmid: 15773874].
68 Katz NP, Adams EH, Benneyan JC, et al. Foundations of opioid risk management. Clin J Pain. Feb. 1. 2007;23(2):103-18. [pmid: 17237659].
69 Trescot AM, Boswell MV, Atluri SL, et al. Opioid guidelines in the management of chronic non-cancer pain. Pain Physician. Jan. 1. 2006;9(1):1-39. [pmid: 16700278].
70 Morrison RS, Wallenstein S, Natale DK, et al. “We don't carry that”—failure of pharmacies in predominantly nonwhite neighborhoods to stock opioid analgesics. N Engl J Med. Apr. 6. 2000;342(14):1023-6. [pmid: 10749965].
71 U.S. Food and Drug Administration. Opioid Drugs and Risk Evaluation and Mitigation Strategies (REMS). Available at: http://www.fda.gov/Drugs/DrugSafety/InformationbyDrugClass/ucm163647.htm. January 4, 2011.
72 Benner DE. Who Can Help Me? A Chronic Pain Patient's View of Multidisciplinary Treatment. Schatman ME, Campbell A, editors. Chronic pain management: guidelines for multidisciplinary program development. New York. Informa Healthcare USA. 2007:117-27.
73 Lebovits A. Ethics and pain: why and for whom?. Pain Med. Jun. 1. 2001;2(2):92-6. [pmid: 15102296].
74 Meldrum ML. A capsule history of pain management. JAMA. Nov. 12. 2003;290(18):2470-5. [pmid: 14612484].
75 Livingston WK. Pain and Suffering. Seattle, WA. International Association for the Study of Pain Press. 1998.
76 Dworkin SF, Von Korff M, LeResch L. Epidemiologic studies of chronic pain: A dynamic-ecologic perspective. Annals of Behavioral Medicine. 1992;14:3-11.
77 Turk DC, Flor H. Chronic Pain: A Biobehavioral Perspective. Gatchel RJ, Turk DC, editors. Psychosocial Factors in Pain. New York. The Guilford Press. 1999:18-34.
78 Deardorff WW, Rubin HS, Scott DW. Comprehensive multidisciplinary treatment of chronic pain: a follow-up study of treated and non-treated groups. Pain. Apr. 1991;45(1):35-43. [pmid: 1861876].
79 Pfingsten M, Hildebrandt J, Leibing E, et al. Effectiveness of a multimodal treatment program for chronic low-back pain. Pain. Oct. 1997;73(1):77-85. [pmid: 9414059].
80 Mayer T, McMahon MJ, Gatchel RJ, et al. Socioeconomic outcomes of combined spine surgery and functional restoration in workers' compensation spinal disorders with matched controls. Spine. Mar. 1. 1998;23(5):598-605. discussion 6. [pmid: 9530792].
81 Turner-Stokes L, Erkeller-Yuksel F, Miles A, et al. Outpatient cognitive behavioral pain management programs: a randomized comparison of a group-based multidisciplinary versus an individual therapy model. Archives of Physical Medicine & Rehabilitation. Jun. 2003;84(6):781-8. [pmid: 12808527].
82 Perry KN, Nicholas MK, Middleton JW. Comparison of a pain management program with usual care in a pain management center for people with spinal cord injury-related chronic pain. Clinical Journal of Pain. Mar-Apr. 2010;26(3):206-16. [pmid: 20173434].
83 Bendix T, Bendix A, Labriola M, et al. Functional restoration versus outpatient physical training in chronic low back pain: a randomized comparative study. Spine. Oct. 1. 2000;25(19):2494-500. [pmid: 11013502].
84 Bendix AF, Bendix T, Lund C, et al. Comparison of three intensive programs for chronic low back pain patients: a prospective, randomized, observer-blinded study with one-year follow-up. Scandinavian Journal of Rehabilitation Medicine. Jun. 1997;29(2):81-9. [pmid: 9198257].
85 Guck TP, Fleischer TD, Willcockson JC, et al. Predictive validity of the pain and impairment relationship scale in a chronic nonmalignant pain population. Archives of Physical Medicine & Rehabilitation. Jan. 1999;80(1):91-5. [pmid: 9915378].
86 Bendix AF, Bendix T, Ostenfeld S, et al. Active treatment programs for patients with chronic low back pain: a prospective, randomized, observer-blinded study. European Spine Journal. 1995;4(3):148-52. [pmid: 7552649].
87 Gatchel RJ, McGeary DD, Peterson A, et al. Preliminary findings of a randomized controlled trial of an interdisciplinary military pain program. Military Medicine. Mar. 2009;174(3):270-7. [pmid: 19354091].
88 Ravenek MJ, Hughes ID, Ivanovich N, et al. A systematic review of multidisciplinary outcomes in the management of chronic low back pain. Work. 2010;35(3):349-67. [pmid: 20364056].
89 van Geen JW, Edelaar MJA, Janssen M, et al. The long-term effect of multidisciplinary back training: a systematic review. Spine. Jan. 15. 2007;32(2):249-55. [pmid: 17224822].
90 Poiraudeau S, Rannou F, Revel M. Functional restoration programs for low back pain: a systematic review. Annales de Readaptation et de Medecine Physique. 2007. Jul. 2007;50(6):425-9. [pmid: 17512079].
91 Chou R, Huffman LH, American Pain S, et al. Nonpharmacologic therapies for acute and chronic low back pain: a review of the evidence for an American Pain Society/American College of Physicians clinical practice guideline. Annals of Internal Medicine. Oct. 2. 2007;147(7):492-504. [pmid: 17909210].
92 van der Hulst M, Vollenbroek-Hutten MMR, Ijzerman MJ. A systematic review of sociodemographic, physical, and psychological predictors of multidisciplinary rehabilitation-or, back school treatment outcome in patients with chronic low back pain. Spine. Apr. 1. 2005;30(7):813-25. [pmid: 15803086].
93 Uhlig T, Finset A, Kvien TK. Effectiveness and cost-effectiveness of comprehensive rehabilitation programs. Current Opinion in Rheumatology. Mar. 2003;15(2):134-40. [pmid: 12598801].
94 Thomsen AB, Sorensen J, Sjogren P, et al. Economic evaluation of multidisciplinary pain management in chronic pain patients: a qualitative systematic review. Journal of Pain & Symptom Management. Aug. 2001;22(2):688-98. [pmid: 11495715].
95 Nielson WR, Weir R. Biopsychosocial approaches to the treatment of chronic pain. Clinical Journal of Pain. Dec. 2001;17(4 Suppl):S114-27. [pmid: 11783824].
96 Alaranta H, Rytokoski U, Rissanen A, et al. Intensive physical and psychosocial training program for patients with chronic low back pain. A controlled clinical trial. Spine. Jun. 15. 1994;19(12):1339-49. [pmid: 8066514].
97 Altmaier EM, Lehmann TR, Russell DW, et al. The effectiveness of psychological interventions for the rehabilitation of low back pain: a randomized controlled trial evaluation. Pain. Jun. 1992;49(3):329-35. [pmid: 1408299].
98 Andary MT, Crewe N, Ganzel SK, et al. Traumatic brain injury/chronic pain syndrome: a case comparison study. Clinical Journal of Pain. Sep. 1997;13(3):244-50. [pmid: 9303257].
99 Bailey BE, Freedenfeld RN, Kiser RS, et al. Lifetime physical and sexual abuse in chronic pain patients: psychosocial correlates and treatment outcomes. Disability & Rehabilitation. Apr. 8. 2003;25(7):331-42. [pmid: 12745957].
100 Bendix AE, Bendix T, Haestrup C, et al. A prospective, randomized 5-year follow-up study of functional restoration in chronic low back pain patients. European Spine Journal. 1998;7(2):111-9. [pmid: 9629934].
101 Bendix AF, Bendix T, Haestrup C. Can it be predicted which patients with chronic low back pain should be offered tertiary rehabilitation in a functional restoration program? A search for demographic, socioeconomic, and physical predictors. Spine. Aug. 15. 1998;23(16):1775-83. discussion 83-4. [pmid: 9728378].
102 Bendix AF, Bendix T, Labriola M, et al. Functional restoration for chronic low back pain. Two-year follow-up of two randomized clinical trials. Spine. Mar. 15. 1998;23(6):717-25. [pmid: 9549794].
103 Bliokas VV, Cartmill TK, Nagy BJ. Does systematic graded exposure in vivo enhance outcomes in multidisciplinary chronic pain management groups?. Clinical Journal of Pain. May. 2007;23(4):361-74. [pmid: 17449998].
104 Buchner M, Zahlten-Hinguranage A, Schiltenwolf M, et al. Therapy outcome after multidisciplinary treatment for chronic neck and chronic low back pain: a prospective clinical study in 365 patients. Scandinavian Journal of Rheumatology. Sep-Oct. 2006;35(5):363-7. [pmid: 17062436].
105 Buchner M, Neubauer E, Zahlten-Hinguranage A, et al. Age as a predicting factor in the therapy outcome of multidisciplinary treatment of patients with chronic low back pain—a prospective longitudinal clinical study in 405 patients. Clinical Rheumatology. Mar. 2007;26(3):385-92. [pmid: 16865309].
106 Buchner M, Neubauer E, Zahlten-Hinguranage A, et al. The influence of the grade of chronicity on the outcome of multidisciplinary therapy for chronic low back pain. Spine. Dec. 15. 2007;32(26):3060-6. [pmid: 18091502].
107 Burns JW. Repression predicts outcome following multidisciplinary treatment of chronic pain. Health Psychology. Jan. 2000;19(1):75-84. [pmid: 10711590].
108 Burns JW, Johnson BJ, Devine J, et al. Anger management style and the prediction of treatment outcome among male and female chronic pain patients. Behaviour Research & Therapy. Nov. 1998;36(11):1051-62. [pmid: 9737057].
109 Burns JW, Johnson BJ, Mahoney N, et al. Cognitive and physical capacity process variables predict long-term outcome after treatment of chronic pain. Journal of Consulting & Clinical Psychology. Apr. 1998;66(2):434-9. [pmid: 9583347].
110 Burns JW, Glenn B, Bruehl S, et al. Cognitive factors influence outcome following multidisciplinary chronic pain treatment: a replication and extension of a cross-lagged panel analysis. Behaviour Research & Therapy. Oct. 2003;41(10):1163-82. [pmid: 12971938].
111 Burns JW, Kubilus A, Bruehl S, et al. Do changes in cognitive factors influence outcome following multidisciplinary treatment for chronic pain? A cross-lagged panel analysis. Journal of Consulting & Clinical Psychology. Feb. 2003;71(1):81-91. [pmid: 12602428].
112 Burns JW, Glenn B, Lofland K, et al. Stages of change in readiness to adopt a self-management approach to chronic pain: the moderating role of early-treatment stage progression in predicting outcome. Pain. Jun. 2005;115(3):322-31. [pmid: 15911159].
113 Carleton RN, Abrams MP, Kachur SS, et al. A comparison of anatomical pain sites from a tertiary care sample: evidence of disconnect between functional and perceived disability specific to lower back pain. European Journal of Pain: Ejp. Apr. 2010;14(4):410-7.
114 Cassisi JE, Sypert GW, Salamon A, et al. Independent evaluation of a multidisciplinary rehabilitation program for chronic low back pain. Neurosurgery. Dec. 1989;25(6):877-83. [pmid: 2532308].
115 Chapman SL, Brena SF. Patterns of conscious failure to provide accurate self-report data in patients with low back pain. Clinical Journal of Pain. Sep. 1990;6(3):178-90. [pmid: 2152011].
116 Chapman SL, Pemberton JS. Prediction of treatment outcome from clinically derived MMPI clusters in rehabilitation for chronic low back pain. Clinical Journal of Pain. Dec. 1994;10(4):267-76. [pmid: 7858355].
117 Chapman SL, Jamison RN, Sanders SH. Treatment Helpfulness Questionnaire: a measure of patient satisfaction with treatment modalities provided in chronic pain management programs. Pain. Dec. 1996;68(2-3):349-61. [pmid: 9121824].
118 Ciechanowski P, Sullivan M, Jensen M, et al. The relationship of attachment style to depression, catastrophizing and health care utilization in patients with chronic pain. Pain. Aug. 2003;104(3):627-37. [pmid: 12927635].
119 Connally GH, Sanders SH. Predicting low back pain patients' response to lumbar sympathetic nerve blocks and interdisciplinary rehabilitation: the role of pretreatment overt pain behavior and cognitive coping strategies. Pain. Feb. 1991;44(2):139-46. [pmid: 1828875].
120 Cott A, Anchel H, Goldberg WM, et al. Non-institutional treatment of chronic pain by field management: an outcome study with comparison group. Pain. Feb. 1990;40(2):183-94. [pmid: 2308764].
121 Crisostomo RA, Schmidt JE, Hooten WM, et al. Withdrawal of analgesic medication for chronic low-back pain patients: improvement in outcomes of multidisciplinary rehabilitation regardless of surgical history. American Journal of Physical Medicine & Rehabilitation. Jul. 2008;87(7):527-36. [pmid: 18574345].
122 Davis VP, Fillingim RB, Doleys DM, et al. Assessment of aerobic power in chronic pain patients before and after a multi-disciplinary treatment program. Archives of Physical Medicine & Rehabilitation. Aug. 1992;73(8):726-9. [pmid: 1642522].
123 Demoulin C, Grosdent S, Capron L, et al. Effectiveness of a semi-intensive multidisciplinary outpatient rehabilitation program in chronic low back pain. Joint, Bone, Spine: Revue du Rhumatisme. Jan. 2010;77(1):58-63.
124 Dersh J, Mayer TG, Gatchel RJ, et al. Prescription opioid dependence is associated with poorer outcomes in disabling spinal disorders. Spine. Sep. 15. 2008;33(20):2219-27. [pmid: 18725868].
125 Doleys DM, Dolce JJ, Doleys AL, et al. Evaluation, narcotics and behavioral treatment influences on pain ratings in chronic pain patients. Archives of Physical Medicine & Rehabilitation. Jul. 1986;67(7):456-8. [pmid: 3729690].
126 Dunstan DA, Covic T. Can a rural community-based work-related activity program make a difference for chronic pain-disabled injured workers?. Australian Journal of Rural Health. Jun. 2007;15(3):166-71. [pmid: 17542788].
127 Dysvik E, Vinsnes AG, Eikeland OJ. The effectiveness of a multidisciplinary pain management programme managing chronic pain. International Journal of Nursing Practice. Oct. 2004;10(5):224-34. [pmid: 15461692].
128 Dysvik E, Natvig GK, Eikeland OJ, et al. Results of a multidisciplinary pain management program: a 6- and 12-month follow-up study. Rehabilitation Nursing. Sep-Oct. 2005;30(5):198-206. [pmid: 16175925].
129 Edwards RR, Doleys DM, Lowery D, et al. Pain tolerance as a predictor of outcome following multidisciplinary treatment for chronic pain: differential effects as a function of sex. Pain. Dec. 2003;106(3):419-26. [pmid: 14659525].
130 Elkayam O, Ben Itzhak S, Avrahami E, et al. Multidisciplinary approach to chronic back pain: prognostic elements of the outcome. Clinical & Experimental Rheumatology. May-Jun. 1996;14(3):281-8. [pmid: 8809442].
131 Elkayam O, Avrahami E, Yaron M. The lack of prognostic value of computerized tomography imaging examinations in patients with chronic non-progressive back pain. Rheumatology International. 1996;16(1):19-21. [pmid: 8783418].
132 Ersek M, Turner JA, Cain KC, et al. Results of a randomized controlled trial to examine the efficacy of a chronic pain self-management group for older adults [ISRCTN11899548]. Pain. Aug. 15. 2008;138(1):29-40. [pmid: 18086516].
133 Evans TH, Mayer TG, Gatchel RJ. Recurrent disabling work-related spinal disorders after prior injury claims in a chronic low back pain population. Spine Journal: Official Journal of the North American Spine Society. May-Jun. 2001;1(3):183-9.
134 Feuerstein M, Callan-Harris S, Hickey P, et al. Multidisciplinary rehabilitation of chronic work-related upper extremity disorders. Long-term effects. Journal of Occupational Medicine. Apr. 1993;35(4):396-403. [pmid: 8487118].
135 Fishbain DA, Lewis J, Cole B, et al. Multidisciplinary pain facility treatment outcome for pain-associated fatigue. Pain Medicine. Jul-Aug. 2005;6(4):299-304. [pmid: 16083460].
136 Flavell HA, Carrafa GP, Thomas CH, et al. Managing chronic back pain: impact of an interdisciplinary team approach. Medical Journal of Australia. Sep. 2. 1996;165(5):253-5. [pmid: 8816681].
137 France RD, Urban BJ. Cerebrospinal fluid concentrations of beta-endorphin in chronic low back pain patients. Influence of depression and treatment. Psychosomatics. 1991;32(1):72-7. [pmid: 1825885].
138 Fricton JR, Olsen T. Predictors of outcome for treatment of temporomandibular disorders. Journal of Orofacial Pain. 1996;10(1):54-65. [pmid: 8995917].
139 Gagnon S, Lensel-Corbeil G, Duquesnoy B, et al. [Multicenter multidisciplinary training program for chronic low back pain: French experience of the Renodos back pain network (Reseau Nord-Pas-de-Calais du DOS)]. Annals of Physical & Rehabilitation Medicine. Feb. 2009;52(1):3-16. [pmid: 19419655].
140 Garcy P, Mayer T, Gatchel RJ. Recurrent or new injury outcomes after return to work in chronic disabling spinal disorders. Tertiary prevention efficacy of functional restoration treatment. Spine. Apr. 15. 1996;21(8):952-9. [pmid: 8726199].
141 Gatchel RJ, Mayer TG, Capra P, et al. Million Behavioral Health Inventory: its utility in predicting physical function in patients with low back pain. Archives of Physical Medicine & Rehabilitation. Dec. 1986;67(12):878-82. [pmid: 2948479].
142 Gatchel RJ, Mayer TG, Capra P, et al. Quantification of lumbar function. Part 6: The use of psychological measures in guiding physical functional restoration. Spine. Jan-Feb. 1986;11(1):36-42. [pmid: 2939568].
143 Gatchel RJ, Polatin PB, Mayer TG, et al. Psychopathology and the rehabilitation of patients with chronic low back pain disability. Archives of Physical Medicine & Rehabilitation. Jun. 1994;75(6):666-70. [pmid: 8002766].
144 Gatchel RJ, Mayer T, Dersh J, et al. The association of the SF-36 health status survey with 1-year socioeconomic outcomes in a chronically disabled spinal disorder population. Spine. Oct. 15. 1999;24(20):2162-70. [pmid: 10543016].
145 Gatchel RJ, Noe CE, Pulliam C, et al. A preliminary study of multidimensional pain inventory profile differences in predicting treatment outcome in a heterogeneous cohort of patients with chronic pain. Clinical Journal of Pain. May-Jun. 2002;18(3):139-43. [pmid: 12048414].
146 Gatchel RJ, Mayer TG, Kidner CL, et al. Are gender, marital status or parenthood risk factors for outcome of treatment for chronic disabling spinal disorders?. Journal of Occupational Rehabilitation. Jun. 2005;15(2):191-201. [pmid: 15844676].
147 Gatchel RJ, Mayer TG. Testing minimal clinically important difference: consensus or conundrum?. Spine Journal: Official Journal of the North American Spine Society. Apr. 2010;10(4):321-7.
148 Glenn B, Burns JW. Pain self-management in the process and outcome of multidisciplinary treatment of chronic pain: evaluation of a stage of change model. Journal of Behavioral Medicine. Oct. 2003;26(5):417-33. [pmid: 14593851].
149 Gross DP, Battie MC. Predicting timely recovery and recurrence following multidisciplinary rehabilitation in patients with compensated low back pain. Spine. Jan. 15. 2005;30(2):235-40. [pmid: 15644763].
150 Guck TP, Meilman PW, Skultety FM, et al. Pain-patient Minnesota Multiphasic Personality Inventory (MMPI) subgroups: evaluation of long-term treatment outcome. Journal of Behavioral Medicine. Apr. 1988;11(2):159-69. [pmid: 3172189].
151 Hatten AL, Gatchel RJ, Polatin PB, et al. A cost-utility analysis of chronic spinal pain treatment outcomes: converting SF-36 data into quality-adjusted life years. Clinical Journal of Pain. Oct. 2006;22(8):700-11. [pmid: 16988566].
152 Hazard RG, Fenwick JW, Kalisch SM, et al. Functional restoration with behavioral support. A one-year prospective study of patients with chronic low-back pain. Spine. Feb. 1989;14(2):157-61. [pmid: 2522243].
153 Hazard RG, Bendix A, Fenwick JW. Disability exaggeration as a predictor of functional restoration outcomes for patients with chronic low-back pain. Spine. Sep. 1991;16(9):1062-7. [pmid: 1835162].
154 Hazard RG, Spratt KF, McDonough CM, et al. The impact of personal functional goal achievement on patient satisfaction with progress one year following completion of a functional restoration program for chronic disabling spinal disorders. Spine. Dec. 1. 2009;34(25):2797-802. [pmid: 19910869].
155 Hildebrandt J, Pfingsten M, Saur P, et al. Prediction of success from a multidisciplinary treatment program for chronic low back pain. Spine. May. 1. 1997;22(9):990-1001. [pmid: 9152449].
156 Hooten WM, Townsend CO, Bruce BK, et al. Sex differences in characteristics of smokers with chronic pain undergoing multidisciplinary pain rehabilitation. Pain Medicine. Nov. 2009;10(8):1416-25. [pmid: 19732372].
157 Hooten WM, Townsend CO, Bruce BK, et al. The effects of smoking status on opioid tapering among patients with chronic pain. Anesthesia & Analgesia. Jan. 2009;108(1):308-15. [pmid: 19095867].
158 Howard KJ, Mayer TG, Gatchel RJ. Effects of presenteeism in chronic occupational musculoskeletal disorders: stay at work is validated. Journal of Occupational & Environmental Medicine. Jun. 2009;51(6):724-31. [pmid: 19430314].
159 Huge V, Schloderer U, Steinberger M, et al. Impact of a functional restoration program on pain and health-related quality of life in patients with chronic low back pain. Pain Medicine. Nov-Dec. 2006;7(6):501-8. [pmid: 17112363].
160 Jensen I, Nygren A, Gamberale F, et al. The role of the psychologist in multidisciplinary treatments for chronic neck and shoulder pain: a controlled cost-effectiveness study. Scandinavian Journal of Rehabilitation Medicine. Mar. 1995;27(1):19-26. [pmid: 7792546].
161 Jensen IB, Nygren A, Lundin A. Cognitive-behavioural treatment for workers with chronic spinal pain: a matched and controlled cohort study in Sweden. Occupational & Environmental Medicine. Mar. 1994;51(3):145-51. [pmid: 8130841].
162 Jensen IB, Bodin L. Multimodal cognitive-behavioural treatment for workers with chronic spinal pain: a matched cohort study with an 18-month follow-up. Pain. May. 1998;76(1-2):35-44. [pmid: 9696457].
163 Jensen MP, Strom SE, Turner JA, et al. Validity of the Sickness Impact Profile Roland scale as a measure of dysfunction in chronic pain patients. Pain. Aug. 1992;50(2):157-62. [pmid: 1408311].
164 Jensen MP, Turner JA, Romano JM. Correlates of improvement in multidisciplinary treatment of chronic pain. Journal of Consulting & Clinical Psychology. Feb. 1994;62(1):172-9. [pmid: 8034820].
165 Jensen MP, Turner JA, Romano JM. Changes in beliefs, catastrophizing, and coping are associated with improvement in multidisciplinary pain treatment. Journal of Consulting & Clinical Psychology. Aug. 2001;69(4):655-62. [pmid: 11550731].
166 Jensen MP, Turner JA, Romano JM. Changes after multidisciplinary pain treatment in patient pain beliefs and coping are associated with concurrent changes in patient functioning. Pain. Sep. 2007;131(1-2):38-47. [pmid: 17250963].
167 Jousset N, Fanello S, Bontoux L, et al. Effects of functional restoration versus 3 hours per week physical therapy: a randomized controlled study. Spine. Mar. 1. 2004;29(5):487-93. discussion 94. [pmid: 15129059].
168 Kaapa EH, Frantsi K, Sarna S, et al. Multidisciplinary group rehabilitation versus individual physiotherapy for chronic nonspecific low back pain: a randomized trial. Spine. Feb. 15. 2006;31(4):371-6. [pmid: 16481945].
169 Kenny DT, Faunce G. The impact of group singing on mood, coping, and perceived pain in chronic pain patients attending a multidisciplinary pain clinic. Journal of Music Therapy. 2004;41(3):241-58. [pmid: 15327342].
170 Keogh E, McCracken LM, Eccleston C. Do men and women differ in their response to interdisciplinary chronic pain management?. Pain. Mar. 2005;114(1-2):37-46. [pmid: 15733629].
171 Kidner CL, Mayer TG, Gatchel RJ. Higher opioid doses predict poorer functional outcome in patients with chronic disabling occupational musculoskeletal disorders. Journal of Bone & Joint Surgery—American Volume. Apr. 2009;91(4):919-27.
172 Kleinke CL, Spangler AS Jr. Psychometric analysis of the audiovisual taxonomy for assessing pain behavior in chronic back-pain patients. Journal of Behavioral Medicine. Feb. 1988;11(1):83-94. [pmid: 2966863].
173 Kohles S, Barnes D, Gatchel RJ, et al. Improved physical performance outcomes after functional restoration treatment in patients with chronic low-back pain. Early versus recent training results. Spine. Dec. 1990;15(12):1321-4. [pmid: 2149211].
174 Kole-Snijders AM, Vlaeyen JW, Goossens ME, et al. Chronic low-back pain: what does cognitive coping skills training add to operant behavioral treatment? Results of a randomized clinical trial. Journal of Consulting & Clinical Psychology. Dec. 1999;67(6):931-44. [pmid: 10596514].
175 Koopman FS, Edelaar M, Slikker R, et al. Effectiveness of a multidisciplinary occupational training program for chronic low back pain: a prospective cohort study. American Journal of Physical Medicine & Rehabilitation. Feb. 2004;83(2):94-103. [pmid: 14758295].
176 Lang E, Liebig K, Kastner S, et al. Multidisciplinary rehabilitation versus usual care for chronic low back pain in the community: effects on quality of life. Spine Journal: Official Journal of the North American Spine Society. Jul-Aug. 2003;3(4):270-6.
177 Law RYW, Harvey LA, Nicholas MK, et al. Stretch exercises increase tolerance to stretch in patients with chronic musculoskeletal pain: a randomized controlled trial. Physical Therapy. Oct. 2009;89(10):1016-26. [pmid: 19696119].
178 Luoto S, Taimela S, Hurri H, et al. Psychomotor speed and postural control in chronic low back pain patients A controlled follow-up study. Spine. Nov. 15. 1996;21(22):2621-7. [pmid: 8961450].
179 Luoto S, Aalto H, Taimela S, et al. One-footed and externally disturbed two-footed postural control in patients with chronic low back pain and healthy control subjects. A controlled study with follow-up. Spine. Oct. 1. 1998;23(19):2081-9. discussion 9-90. [pmid: 9794052].
180 Lynch RT, Agre J, Powers JM, et al. Long-term follow-up of outpatient interdisciplinary pain management with a no-treatment comparison group. American Journal of Physical Medicine & Rehabilitation. May-Jun. 1996;75(3):213-22. [pmid: 8663930].
181 Maclaren JE, Gross RT, Sperry JA, et al. Impact of opioid use on outcomes of functional restoration. Clinical Journal of Pain. May. 2006;22(4):392-8. [pmid: 16691094].
182 Man AKY, Chu MC, Chen PP, et al. Clinical experience with a chronic pain management programme in Hong Kong Chinese patients. Hong Kong Medical Journal. Oct. 2007;13(5):372-8. [pmid: 17914143].
183 Mangels M, Schwarz S, Worringen U, et al. Evaluation of a behavioral-medical inpatient rehabilitation treatment including booster sessions: a randomized controlled study. Clinical Journal of Pain. Jun. 2009;25(5):356-64. [pmid: 19454868].
184 Maruta T, Swanson DW, McHardy MJ. Three year follow-up of patients with chronic pain who were treated in a multidisciplinary pain management center. Pain. Apr. 1990;41(1):47-53. [pmid: 2352766].
185 Mayer T, Tabor J, Bovasso E, et al. Physical progress and residual impairment quantification after functional restoration. Part I: Lumbar mobility. Spine. Feb. 15. 1994;19(4):389-94. [pmid: 8178224].
186 Mayer T, Gatchel RJ, Evans T. Effect of age on outcomes of tertiary rehabilitation for chronic disabling spinal disorders. Spine. Jun. 15. 2001;26(12):1378-84. [pmid: 11426155].
187 Mayer T, Aceska A, Gatchel RJ. Is obesity overrated as a “risk factor” for poor outcomes in chronic occupational spinal disorders?. Spine. Dec. 1. 2006;31(25):2967-72. [pmid: 17139229].
188 Mayer TG, Gatchel RJ, Kishino N, et al. A prospective short-term study of chronic low back pain patients utilizing novel objective functional measurement. Pain. Apr. 1986;25(1):53-68. [pmid: 2940500].
189 Mayer TG, Gatchel RJ, Mayer H, et al. A prospective two-year study of functional restoration in industrial low back injury. An objective assessment procedure. [Erratum appears in JAMA 1988 Jan 8;259(2):220]. JAMA. Oct. 2. 1987;258(13):1763-7. [pmid: 2957520].
190 Mayer TG, Barnes D, Nichols G, et al. Progressive isoinertial lifting evaluation. II. A comparison with isokinetic lifting in a disabled chronic low-back pain industrial population. [Erratum appears in Spine 1990 Jan;15(1):5]. Spine. Sep. 1988;13(9):998-1002. [pmid: 2974633].
191 Mayer TG, Anagnostis C, Gatchel RJ, et al. Impact of functional restoration after anterior cervical fusion on chronic disability in work-related neck pain. Spine Journal: Official Journal of the North American Spine Society. Jul-Aug. 2002;2(4):267-73.
192 Mayer TG, Towns BL, Neblett R, et al. Chronic widespread pain in patients with occupational spinal disorders: prevalence, psychiatric comorbidity, and association with outcomes. Spine. Aug. 1. 2008;33(17):1889-97. [pmid: 18670343].
193 McCracken LM, Vowles KE, Eccleston C. Acceptance-based treatment for persons with complex, long standing chronic pain: a preliminary analysis of treatment outcome in comparison to a waiting phase. Behaviour Research & Therapy. Oct. 2005;43(10):1335-46. [pmid: 16086984].
194 Michaelson P, Sjolander P, Johansson H. Factors predicting pain reduction in chronic back and neck pain after multimodal treatment. Clinical Journal of Pain. Nov-Dec. 2004;20(6):447-54. [pmid: 15502689].
195 Middaugh SJ, Levin RB, Kee WG, et al. Chronic pain: its treatment in geriatric and younger patients. Archives of Physical Medicine & Rehabilitation. Dec. 1988;69(12):1021-6. [pmid: 3214260].
196 Mohler SN, Tarrant JD. Multidisciplinary treatment of chronic craniomandibular disorder: a preliminary investigation. Cranio. Jan. 1991;9(1):29-34. [pmid: 1843476].
197 Norrefalk JR, Svensson O, Ekholm J, et al. Can the back-to-work rate of patients with long-term non-malignant pain be predicted?. International Journal of Rehabilitation Research. Mar. 2005;28(1):9-16. [pmid: 15729092].
198 Norrefalk JR, Ekholm J, Borg K. Ethnic background does not influence outcome for return-to-work in work-related interdisciplinary rehabilitation for long-term pain: 1- and 3-year follow-up. Journal of Rehabilitation Medicine. Mar. 2006;38(2):87-92. [pmid: 16546764].
199 Norrefalk JR, Linder J, Ekholm J, et al. A 6-year follow-up study of 122 patients attending a multiprofessional rehabilitation programme for persistent musculoskeletal-related pain. International Journal of Rehabilitation Research. Mar. 2007;30(1):9-18. [pmid: 17293715].
200 Norrefalk JR, Ekholm K, Linder J, et al. Evaluation of a multiprofessional rehabilitation programme for persistent musculoskeletal-related pain: economic benefits of return to work. Journal of Rehabilitation Medicine. Jan. 2008;40(1):15-22. [pmid: 18176732].
201 Olason M. Outcome of an interdisciplinary pain management program in a rehabilitation clinic. Work. 2004;22(1):9-15. [pmid: 14757900].
202 Patrick LE, Altmaier EM, Found EM. Long-term outcomes in multidisciplinary treatment of chronic low back pain: results of a 13-year follow-up. Spine. Apr. 15. 2004;29(8):850-5. [pmid: 15082983].
203 Polatin PB, Gatchel RJ, Barnes D, et al. A psychosociomedical prediction model of response to treatment by chronically disabled workers with low-back pain. Spine. Sep. 1989;14(9):956-61. [pmid: 2528825].
204 Polatin PB, Cox B, Gatchel RJ, et al. A prospective study of Waddell signs in patients with chronic low back pain. When they may not be predictive. Spine. Jul. 15. 1997;22(14):1618-21. [pmid: 9253098].
205 Proctor TJ, Mayer TG, Gatchel RJ, et al. Unremitting health-care-utilization outcomes of tertiary rehabilitation of patients with chronic musculoskeletal disorders. Journal of Bone & Joint Surgery—American Volume. Jan. 2004;86-A(1):62-9.
206 Proctor TJ, Mayer TG, Theodore B, et al. Failure to complete a functional restoration program for chronic musculoskeletal disorders: a prospective 1-year outcome study. [Erratum appears in Arch Phys Med Rehabil. 2005 Nov;86(11):2228]. Archives of Physical Medicine & Rehabilitation. Aug. 2005;86(8):1509-15. [pmid: 16084800].
207 Protas EJ, Mayer TG, Dersh J, et al. Relevance of aerobic capacity measurements in the treatment of chronic work-related spinal disorders. Spine. Oct. 1. 2004;29(19):2158-66. discussion 67. [pmid: 15454709].
208 Rainville J, Ahern DK, Phalen L, et al. The association of pain with physical activities in chronic low back pain. Spine. Sep. 1992;17(9):1060-4. [pmid: 1411757].
209 Rainville J, Ahern DK, Phalen L. Altering beliefs about pain and impairment in a functionally oriented treatment program for chronic low back pain. Clinical Journal of Pain. Sep. 1993;9(3):196-201. [pmid: 8219520].
210 Rome JD, Townsend CO, Bruce BK, et al. Chronic noncancer pain rehabilitation with opioid withdrawal: comparison of treatment outcomes based on opioid use status at admission. Mayo Clinic Proceedings. Jun. 2004;79(6):759-68. [pmid: 15182090].
211 Scerri M, de Goumoens P, Fritsch C, et al. The INTERMED questionnaire for predicting return to work after a multidisciplinary rehabilitation program for chronic low back pain. Joint, Bone, Spine: Revue du Rhumatisme. Dec. 2006;73(6):736-41.
212 Skinner JB, Erskine A, Pearce S, et al. The evaluation of a cognitive behavioural treatment programme in outpatients with chronic pain. Journal of Psychosomatic Research. 1990;34(1):13-9. [pmid: 2313610].
213 Skouen JS, Grasdal AL, Haldorsen EMH, et al. Relative cost-effectiveness of extensive and light multidisciplinary treatment programs versus treatment as usual for patients with chronic low back pain on long-term sick leave: randomized controlled study. Spine. May. 1. 2002;27(9):901-9. discussion 9-10. [pmid: 11979157].
214 Snow BR, Gusmorino P, Pinter I, et al. Multidisciplinary treatment of physical and psychosocial disabilities in chronic pain patients: a follow-up report. Bulletin of the Hospital for Joint Diseases Orthopaedic Institute. 1988;48(1):52-61. [pmid: 2840148].
215 Snow BR, Gusmorino P, Pinter I. Multidisciplinary treatment for a chronic pain patient returning to work: a case report. Bulletin of the Hospital for Joint Diseases Orthopaedic Institute. 1990;50(2):200-4. [pmid: 2175668].
216 Spinhoven P, Ter Kuile M, Kole-Snijders AMJ, et al. Catastrophizing and internal pain control as mediators of outcome in the multidisciplinary treatment of chronic low back pain. European Journal of Pain: Ejp. Jun. 2004;8(3):211-9.
217 Stans L, Goossens L, Van Houdenhove B, et al. Evaluation of a brief chronic pain management program: effects and limitations. Clinical Journal of Pain. Dec. 1989;5(4):317-22. [pmid: 2520422].
218 Sterner Y, Lofgren M, Nyberg V, et al. Early interdisciplinary rehabilitation programme for whiplash associated disorders. Disability & Rehabilitation. Jul. 10. 2001;23(10):422-9. [pmid: 11400904].
219 Storro S, Moen J, Svebak S. Effects on sick-leave of a multidisciplinary rehabilitation programme for chronic low back, neck or shoulder pain: comparison with usual treatment. Journal of Rehabilitation Medicine. Jan. 2004;36(1):12-6. [pmid: 15074433].
220 Suoyrjo H, Hinkka K, Oksanen T, et al. Effects of multidisciplinary inpatient rehabilitation for chronic back or neck pain: a register-linkage study of sickness absences and analgesic purchases in an occupational cohort. Occupational & Environmental Medicine. Mar. 2008;65(3):179-84. [pmid: 17940149].
221 Tollison CD, Kriegel ML, Downie GR. Chronic low back pain: results of treatment at the Pain Therapy Center. Southern Medical Journal. Nov. 1985;78(11):1291-5. [pmid: 2933814].
222 Tollison CD, Kriegel ML, Satterthwaite JR. Comprehensive treatment of acute and chronic low back pain: a clinical outcome comparison. Orthopaedic Review. Jan. 1989;18(1):59-64. [pmid: 2521705].
223 Tollison CD, Satterthwaite JR, Kriegel ML, et al. Interdisciplinary treatment of low back pain. A clinical outcome comparison of compensated versus noncompensated groups. Orthopaedic Review. Aug. 1990;19(8):701-6. [pmid: 2145546].
224 Trief PM, Carnrike CL Jr, Drudge O. Chronic pain and depression: is social support relevant?. Psychological Reports. Feb. 1995;76(1):227-36. [pmid: 7770574].
225 van Wilgen CP, Dijkstra PU, Versteegen GJ, et al. Chronic pain and severe disuse syndrome: long-term outcome of an inpatient multidisciplinary cognitive behavioural programme. Journal of Rehabilitation Medicine. Feb. 2009;41(3):122-8. [pmid: 19229443].
226 Vendrig AA. Prognostic factors and treatment-related changes associated with return to work in the multimodal treatment of chronic back pain. Journal of Behavioral Medicine. Jun. 1999;22(3):217-32. [pmid: 10422615].
227 Vendrig AA, Derksen JJ, de Mey HR. MMPI-2 Personality Psychopathology Five (PSY-5) and prediction of treatment outcome for patients with chronic back pain. Journal of Personality Assessment. Jun. 2000;74(3):423-38. [pmid: 10900569].
228 Vendrig AA, van Akkerveeken PF, McWhorter KR. Results of a multimodal treatment program for patients with chronic symptoms after a whiplash injury of the neck. Spine. Jan. 15. 2000;25(2):238-44. [pmid: 10685489].
229 Vines SW, Cox A, Nicoll L, et al. Effects of a multimodal pain rehabilitation program: a pilot study. Rehabilitation Nursing. Jan-Feb. 1996;21(1):25-30. [pmid: 8577978].
230 Vines SW, Ng AK, Breggia A, et al. Multimodal chronic pain rehabilitation program: its effect on immune function, depression, and health behaviors. Rehabilitation Nursing. Sep-Oct. 2000;25(5):185-91. [pmid: 11998084].
231 Vollenbroek-Hutten MMR, Hermens HJ, Wever D, et al. Differences in outcome of a multidisciplinary treatment between subgroups of chronic low back pain patients defined using two multiaxial assessment instruments: the multidimensional pain inventory and lumbar dynamometry. Clinical Rehabilitation. Aug. 2004;18(5):566-79. [pmid: 15293491].
232 Vowles KE, Gross RT, Sorrell JT. Predicting work status following interdisciplinary treatment for chronic pain. European Journal of Pain: Ejp. Aug. 2004;8(4):351-8.
233 Vowles KE, McCracken LM, Eccleston C. Processes of change in treatment for chronic pain: the contributions of pain, acceptance, and catastrophizing. European Journal of Pain: Ejp. Oct. 2007;11(7):779-87.
234 Vowles KE, McCracken LM. Acceptance and values-based action in chronic pain: a study of treatment effectiveness and process. Journal of Consulting & Clinical Psychology. Jun. 2008;76(3):397-407. [pmid: 18540733].
235 Vowles KE, McCracken LM. Comparing the role of psychological flexibility and traditional pain management coping strategies in chronic pain treatment outcomes. Behaviour Research & Therapy. Feb. 2010;48(2):141-6. [pmid: 19853243].
236 Walsh DA, Radcliffe JC. Pain beliefs and perceived physical disability of patients with chronic low back pain. Pain. May. 2002;97(1-2):23-31. [pmid: 12031776].
237 Walsh DA, Jane Kelly S, Sebastian Johnson P, et al. Performance problems of patients with chronic low-back pain and the measurement of patient-centered outcome. Spine. Jan. 1. 2004;29(1):87-93. [pmid: 14699282].
238 Wasan AD, Artin K, Clark MR. A case-matching study of the analgesic properties of electroconvulsive therapy. Pain Medicine. Mar. 2004;5(1):50-8. [pmid: 14996237].
239 Williams AC, Nicholas MK, Richardson PH, et al. Evaluation of a cognitive behavioural programme for rehabilitating patients with chronic pain. British Journal of General Practice. Dec. 1993;43(377):513-8. [pmid: 8312023].
240 Wong M, Rietzschel J, Mulherin D, et al. Evaluation of a multidisciplinary outpatient pain management programme based at a community hospital. Musculoskeletal Care. Jun. 2009;241.
241 Wormgoor MEA, Indahl A, van Tulder MW, et al. The impact of aerobic fitness on functioning in chronic back pain. European Spine Journal. Apr. 2008;17(4):475-83. [pmid: 18057967].
242 Wright A, Mayer TG, Gatchel RJ. Outcomes of disabling cervical spine disorders in compensation injuries. A prospective comparison to tertiary rehabilitation response for chronic lumbar spinal disorders. Spine. Jan. 15. 1999;24(2):178-83. [pmid: 9926390].
243 Zunin ID, Orenstein S, Chang M, et al. Comprehensive Pain Program outcomes evaluation: a preliminary study in Hawai'i. Hawaii Medical Journal. Aug. 2009;68(7):158-617. (2): 106-20. [pmid: 19653417].