# Next Steps

There are several reviews of the current body of research on efficacy of MPPs as treatment for chronic, noncancer pain (examples1,2,88-95). These reviews include discussions of efficacy in various different pain conditions, populations, and treatment modes, as well as noted problems with study designs, outcome measurements, and the difficulty of aggregating information across studies. The most comprehensive systematic review reported qualitative evidence for MPPs effectiveness compared to standard treatment and non-MPP treatment for patients with chronic back pain, fibromyalgia and mixed chronic pain. However, the review also noted the generally low quality of the available studies for review.1

The literature review and interviews we conducted highlighted a number of areas for future research design consideration:

- On the payer side, we have noted from discussions with Key Informants and the grey literature that more detailed information addressing cost-effectiveness is needed. For example, information on which patients are most likely to be helped by MPPs (including research into the genetics and molecular biology of pain), when it is possible to determine that a patient is not responding to treatment and would benefit from a change, and when patients should be referred to MPPs for treatment (e.g., degree of chronicity, which treatments should be attempted first, etc.).
- Given the high rates of treatment attrition and refusal in some programs, attention should also be paid to options for patients who are refused MPP treatment or who do not experience relief, since the MPP is often the treatment of last resort.
- Certain outcomes have been noted to be of special interest to payers, including return to work, which is problematic to define—full-time or part-time? in the same job or a different job? what timeframe should be used?—but worth considering nonetheless, especially for disability and workers' compensation insurers.
- Information about the decrease in the number of programs and the structural support needed to increase access to MPPs would be of interest to legislators and regulators, who may be able to provide special incentives to support these programs.
- The small number of RCTs should ideally be supplemented with additional randomized studies in the United States, since most of those currently available were conducted overseas, in very different public health and occupational contexts.