# Methods

We included information gleaned from discussions with key informants, targeted searching of the grey literature, reviews of various reference materials, and a comprehensive search of the peer-reviewed literature.

## Discussions With Key Informants

We identified several key informants to provide expertise from various perspectives. We included MPP clinicians, third-party payers, consumers, and researchers. Key informants initially participated in discussions aimed at developing the guiding questions for the Technical Brief and provided leads to resources in the peer-reviewed and grey literature. These individuals and their affiliations are listed in Appendix B. Interviews were conducted via telephone or in person, during July and August of 2010. Information requested from each key informant varied based upon their area of expertise. Interview guides were developed in advance, including the topics and questions to be addressed with each group of informants; these guides appear in Appendix B, as well.

## Grey Literature Search

Grey literature describing the MPP and its clinical indications is less important than it would be with a newer technology, given the large peer-reviewed literature. However, where necessary, information from key informants and included studies and reviews was supplemented with grey literature, generally on consumer and payer perspectives.

## Published Literature Search

We conducted literature searches in MEDLINE^®^, from 1985 to the end of May 2010. The start 1985 date was chosen since MPPs proliferated in the 1980's, and it was unlikely literature prior to that period would contribute to the report.32 Searches were limited to studies relevant to humans and published in English. Restricting the research to English language materials was not expected to result in a language bias for this topic and stakeholders.33 A search strategy designed for high sensitivity, rather than specificity, was used, due to the limitations of the Medical Subject Headings (MeSH terms) and the relatively inconsistent use of terminology in this field. The search strategy used with Ovid MEDLINE^®^, including a concept analysis and proposed search terms, is described in Appendix C. An update of the search was conducted April 2011; no new literature was found that altered the findings of this report.

The articles were reviewed using exclusion and inclusion criteria. Articles that addressed acute pain, including chest pain, post-operative pain, etc., were excluded, as were studies that included pediatric populations. Articles that were not studies but addressed a question of interest in the background and context guiding questions were coded separately and retained.

The guiding questions included several areas of interest to be abstracted from the articles, including study design, setting, treatment components, and outcome measures. These data were extracted by one researcher into an Excel spreadsheet for analysis (MMJ). Other researchers provided advice where design features were unusual or ambiguous (MB, RLK).

## Definition of Multidisciplinary Pain Program

We used the following definition of MPP in reviewing studies for inclusion. This definition is consistent with that used in the literature and was refined through discussions with our Key Informants. It requires that each of the four components be included for a treatment program to be classified as an MPP. The components are described here along with examples:

- Medical therapy
  ○ Responsible for patient's physical wellbeing
  ○ Manage medications
  ○ Educational component may be included with medical component (but research study must explicitly state this: e.g., neurophysiology education)
- Behavioral therapy
  ○ Responsible for psychosocial aspects of patients' care
  ○ Cognitive Behavioral Therapy (CBT)
  ○ Operant Behavioral Therapy (OBT)
  ○ Stress management training
  ○ Relaxation, progressive muscle relaxation
  ○ Biofeedback
  ○ Comorbidity diagnosis and treatment
  ○ Help patient unlearn maladaptive responses to pain
  ○ Problem solving
  ○ Individual or group psychotherapy
  ○ Educational component is often included with behavioral (but research study must explicitly state this)
- Physical reconditioning
  ○ Physical Therapy (PT) and/or Occupational Therapy (OT)
  ○ Graduated activity exposure (pacing) enabling patients to control exacerbations in pain by learning to regulate the activity and, once a regime of paced activity is established, to gradually increase their activity level
  ○ Graded therapeutic exercises to safely increase functioning (e.g., flexibility, range of motion, posture, body mechanics, ambulation, gait training, core strength/stability, cardiovascular fitness)
  ○ Passive modes (e.g., ultrasound, electrical stimulation, massage) are generally avoided in MPP and focus is teaching patients independent management of pain
  ○ Stretching and strengthening emphasized
  ○ Job analysis and reconditioning
  ○ Educational component is often included with physical reconditioning (but research study must explicitly state this), e.g., back education
- Education
  ○ Improved self management is the focus
  ○ Educational component is sometimes integrated with one or more other components (e.g., by psychologist with behavioral component, by nurse with medical component, by PT with physical reconditioning component)
  ○ Back education
  ○ Home exercise training
  ○ Ergonomic training
  ○ Neurophysiology education provided by a physician or nurse

Appendix D contains details of the 183 included studies in tables addressing comparison treatments, length of followup, outcomes measured, and other study design information.