# Findings

This section addresses the context in which the MPP is used and the current evidence base on this treatment, focusing on the topics included in Guiding Questions 1 through 3. These topics are called out with bolded or italicized paragraph headings. (Guiding Question 4 is addressed in the summary.)

## Description of Technology and Context for Use

### Accreditation

Accreditation is not centralized for MPPs, at least in part due to the broad range of programs and treatment options available. The definition used in this Brief is one view of MPPs, but there are others possible, both more and less stringent. That said, the most frequently mentioned accreditation program is the Commission on Accreditation of Rehabilitation Facilities' (CARF) Interdisciplinary Pain Rehabilitation, which covers both outpatient and inpatient programs, in-and outside the United States. The other frequently mentioned program is the American Academy of Pain Management's Pain Program Accreditation, which includes a category of Comprehensive Multidisciplinary Program.34

### Availability of Programs

MPPs are available in a variety of settings—international outpatient and inpatient hospitals, rehabilitation facilities, and academic medical centers. As of 2005, there were 84 pain programs in the United States accredited by CARF as Interdisciplinary Pain Rehabilitation Programs.32 A recent search on the CARF website yielded just 64 programs in the United States (including Puerto Rico), with over half of those located in Texas, leaving much of the rest of the country without coverage.35 However, there are MPPs in the United States that are not accredited by CARF. According to Schatman,32 one estimate of the total number of MPPs in the United States in 2005 was 200, of which 84 were CARF accredited. If this ratio remains valid, there may be approximately 150 MPPs remaining in 2011.

### Staffing

Staffing in MPPs varies by center; however, given our definition, each would have at least one physician or nurse, a psychologist or other behavioral therapist, and a physical or occupational therapist. Any of these professionals could provide the education component. CARF accreditation requires that the treatment team include physicians, psychologists, and physical therapists.36 Several authors have outlined possible staffing models for MPPs.32,37-39 One important factor is that the professionals on the team are specifically trained in the care of chronic pain patients, which follows a different care model from both acute pain and non-pain rehabilitation. For example, Schatman notes that the traditional passive modes of treatment physical therapists are trained to use with acute pain patients are inappropriate in the MPP setting.32 With patients with chronic pain, therapists must address both behavioral and emotional sequelae of longstanding pain that stand in the way of successful outcomes. In addition, MPP staff need to work together closely as a team. In fact, at least one study has found that treatment is less successful when one component is “carved out” due to insurer policies—that is, when one part of the treatment is provided outside the program, out of contact with the rest of the team.40

### Other Treatments

Other treatments for chronic pain include partial MPPs, which have some but not all of the components, and procedure-based practices, including such interventions as nerve blocks, discectomy, etc. Though the MPP is often seen as the last resort for intractable pain, it is fundamentally a conservative treatment: other treatments are not necessarily more safe or more effective. Many patients have already exhausted other procedures and less intensive treatment options when they come to the MPP. Even if a patient has not responded to the components when presented separately, advocates of MPP treatment note that there is additional value to providing all four treatment components at once.

### Advantages of Integrated Treatment

The MPP is thought to improve on unimodal treatments by simultaneously addressing the multiple influences on chronic pain in the biopsychosocial model.41 It is also a conservative treatment option that causes few if any adverse effects (see below), especially when compared to surgery or long-term opioid therapy.

### Adverse Effects and Disadvantages

Few, if any, studies mentioned adverse effects due to MPP treatment. One study included an adjunctive heat treatment delivered in a confined sauna-like device; one participant had to withdraw from the treatment due to claustrophobia.42 Treatment protocols that include invasive procedures such as nerve blocks would presumably carry the risks following from those procedures, but there was no indication in the literature of additional risks from combining the different treatments. In a comparative review of the evidence relating to several common chronic pain treatments, Turk and Swanson43 conclude that all treatments considered have possible iatrogenic complications, “perhaps with the exception of MPRPs (Multidisciplinary Pain Rehabilitation Centers).”

Many studies did, however, report some information about attrition (dropping out of treatment), which is generally quite high: ranging from 0 to 48 percent (comparable to the 5 to 46 percent found in one literature review.)44 The average attrition for those studies reporting dropout rates was 11 percent; the median was 9 percent. Attrition could be a marker of an adverse effect as some patient-initiated withdrawal from treatment may be due to increased pain or stress.

Other than as noted, no adverse effects were identified in the literature.

## Evidence Map of Multidisciplinary Pain Programs

The literature search yielded 1194 articles in total. The disposition of those articles is shown in Figure 1. Study inclusion criteria are presented in Appendix C.

Figure 1 Literature search

Figure 1 is a flow chart summarizing the search and selection of articles. There were 1,194 citations identified in Medline. Of these, 51 were excluded because the study populations did not meet our criteria: 47 because they focused on acute pain and 4 because they focused on pediatric populations. 33 citations were excluded as duplicates. 104 articles were excluded because they had only 2 or 3 of the required 4 components used to define Multidisciplinary Pain Programs. 640 articles were excluded for other reasons: having only 1 of the 4 definition components, being off topic, not reporting a study, etc. 183 studies were included: 179 studies from the literature search and 4 studies found in the hand search. Of these, 96 were based in the United States, 68 in Europe, and 19 in the rest of the world. Finally, 190 articles were classified as background and context: 186 from the literature search plus 4 from a hand search.

The literature on MPPs is extensive. Even with the relatively stringent requirements of including each of the four definition components, over 180 papers were found, representing approximately 160 different experiments or observational trials.^ii^ These studies were based in 18 different countries. Approximately half of the papers included (96) were located in the United States. The majority of the remainder was conducted in Europe/United Kingdom (68). A variety of public health contexts are represented by the study countries. This could be important for the outcome of MPPs for a variety of reasons, including access to treatment at the subacute stage, payer policies on behavioral and psychological care, coverage of workplace ergonomic interventions, and the effect of a stronger social safety net, which some researchers have hypothesized may affect chronic pain sufferers' motivation to return to work.45

ii Unless otherwise noted, in this Brief “study” refers to an individual paper, rather than an experiment or observational trial.

Where possible, studies were coded with the name of the treatment center. In several cases, although the study did not state where treatment was provided, it was possible to make an educated guess based on author affiliations and similarities to other studies published from the same treatment center. A total of 85 treatment centers were identified or attributed in the included studies.^iii^ There were an additional 12 treatment centers that could not be readily identified.

iii Where possible, treatment centers that have changed names over the years were combined into a single entry for the purposes of this analysis; in addition, treatment centers with more than one program offering were combined into a single entry as well: for example, the Royal North Shore Hospital in Sydney offers a version of its ADAPT program specifically for patients with permanent paralysis due to spinal cord injury, which is known as SpinalADAPT. These two programs were presented here as a single entity.

A few treatment centers have been extensively documented in the literature. The most notable is the PRIDE center in Dallas, Texas. The treatment program that originated there, known as Functional Restoration,11,46 has been influential in shaping the offerings at many of the other treatment centers included in this Technical Brief. There were 27 papers directly attributed to PRIDE.

### Patient Populations

Almost by definition, since those they treat have pain that has progressed from acute to chronic, most MPPs are treating patients who have failed to gain relief from multiple prior treatments. Some studies specifically noted that they are treating the patients with the most intractable chronic pain, which continues to contribute to significant impairments in physical and emotional function. Some noted that they do not place many restrictions on the incoming patients based on clinical factors like litigation status or most mental health diagnoses^iv^; others require that patients explicitly accede to the treatment philosophy at the center, have no open litigation or workers compensation claims, and be treated for comorbid substance abuse before starting the program. Study exclusion criteria have been abstracted from the included studies in the Brief and are presented in Appendix D, Table D-1.

iv Patients with certain mental health diagnoses are sometimes excluded from MPPs if their condition may preclude productive engagement in group therapy.

Turk and Stacey39 report that between 5 and 54 percent of patients evaluated for treatment in MPPs are turned away, depending on the study. Generally, it is in all parties' best interests to offer treatment only to those who are most likely to benefit—especially in the case of MPP treatments, which require a significant investment of time and energy from the patient and providers, as well as a large financial investment from the payer. In reviewing the most common exclusion criteria, however, Turk and Stacey note that the evidence may not support some of the more frequent bases for refusal, including age, litigation status, and psychological factors.

Many experts on chronic pain have noted that the U.S. system of disability determination can adversely affect patient prognosis. “The work of Crown43 suggests that psychological aberration is acquired as a consequence of negotiating the gauntlet of disability determination for Workers' Compensation…. This ostensibly ethical insurance paradigm is iatrogenic. It is hard, if not impossible, to get well if you have to prove you are sick.”47 In other words, a psychological disorder may be a predictable sequela of the process of obtaining financial coverage for treatment. Seeking or receiving compensation for injuries may be labeled secondary gain and used as a reason to deny treatment. However, at least in the United States, Workers' Compensation insurance offers among the least restricted reimbursement programs for MPP treatment, making occupational injuries especially common diagnoses in these treatment programs and the studies assessing them.

Conditions/diagnoses studied. The identified studies included both studies focused on a single diagnosis or clinical condition, and studies of heterogeneous chronic pain populations. Around half the studies (90 out of 183) included multiple pain conditions, thus including people with very different etiology and clinical courses, generally giving the proportion of the patients with pain in various locations.

An additional 93 studies focused on a single condition, 85 percent of these on back pain. Some of the single condition studies used standard diagnostic categories like Fibromyalgia. Others used criteria that encompass the presumably similar psychosocial experience of, for example, Chronic Occupational Spinal Disorders–patients who were injured at work somewhere along their spine (including cervical, thoracic, and lumbar locations).

The most frequent diagnosis reported in these studies was back pain of some type, generally chronic lower back pain, with 96 studies, plus an additional 16 studies on spine pain, and eight on neck or back pain. Overall, 90 percent of studies included some back pain patients. After back/spine pain, the next most frequent diagnosis was an indeterminate category of “varied/chronic pain,” with 29 studies. Thirteen studies explicitly included patients with fibromyalgia or chronic widespread pain; six studies noted inclusion of headache disorders. No studies specifically studied post-herpetic neuralgia, though these patients were likely included in the “heterogeneous chronic pain” groups, e.g., Wang et al.,48 who included post-herpetic neuralgia in their list of conditions. Jaw pain (craniomandibular and temporomandibular disorder) was the focus of two studies.

Study design: comparison treatments. A minority of studies included a comparison treatment: 67 (37 percent) had at least one comparison treatment (Table 1). Of those studies that included multiple treatments, 36 percent assigned the treatments randomly. This translates to 24 studies with multiple, randomly assigned treatment groups. Three of these used comparison treatments that also met our MPP criteria, so they were not strictly trials of MPP efficacy. Six of the studies included a randomly assigned waiting list condition, five included a randomly assigned no treatment or usual care (outside the MPP) condition.

Table 1 Comparison treatments

Comparison Treatment Studied | N | % Random Assignment to Treatment
No comparison treatment | 116 | N/A
Comparison treatment (all) | 67 | 36%
Alternate treatment
Alternate treatment: Non-MPP | 17 | 65%
Alternate treatment: MPP | 12 | 25%
No alternate treatment
No treatment and non-completers | 14 | 7%
Combination/multiple
Usual care or waiting list | 14 | 14%
Non-MPP treatment and no treatment | 5 | 60%
MPP treatment and waiting list | 4 | 75%
MPP and non-MPP treatments | 1 | 0%
Total | 183

Of the 42 studies including nonrandomly assigned comparison groups (one study did not state whether comparison treatments were assigned randomly) 18 used an active treatment condition (eight included a non-MPP treatment, nine included an MPP treatment, one study included both), the rest used only nonactive comparators (waiting list, usual care, or no treatment).

### Inpatient/Outpatient Treatment

Between 1985 and 2004, there seems to have been a trend away from inpatient treatment programs toward outpatient models, at least in the published literature. This trend is consistent with key informant input suggesting that payers were becoming increasingly reluctant to pay for more expensive inpatient programs. Since 2005, publications appear to show an increase in inpatient programs in Europe (Figure 2). Three studies directly compared the effectiveness of inpatient versus outpatient treatments.49-51

Figure 2 Treatment settings by program location

Note: For simplicity, Australian, Asian, and Icelandic studies are not shown, nor are “other” study designs, which include residential programs and programs where some patients were inpatient while others were outpatients; data from partial year 2010 is not shown.

Figure 2 is a paired stacked column chart comparing treatment settings for studies based in Europe vs. the United States over five 5-year periods from 1985 to 2009. The categories of treatment settings were: outpatient; inpatient or both inpatient and outpatient (referred to here as “inpatient”); and comparison of inpatient and outpatient settings. In 1985-89 and 1990-94, U.S. studies were roughly equally based in inpatient and outpatient settings and were far more numerous than European studies. During the 1995-99 time period, there were equal numbers of studies published in the United States and Europe; all the U.S. studies were outpatient settings, while one-third of the European studies were inpatient or inpatient/outpatient comparisons. During the 2000-04 time period, European and U.S. studies were nearly identical in number and setting, with both regions publishing 16 outpatient studies and 2 inpatient studies. The United States also had one comparison study. In the final time period, 2005-09, there were more European than U.S. studies, and more than half of the European studies were inpatient settings (11 inpatient and 10 outpatient); in contrast, of the 18 U.S. studies, only one had an inpatient setting.

### Measurements and Outcomes

A large number and range of outcomes were assessed by the included studies. These measures ranged from Visual Analog Scales of pain intensity to degrees of lumbar extension and flexion to a variety of return-to-work measures. A consensus statement on the most important outcome domains for chronic pain clinical trials was created by the Initiative on Methods, Measurement, and Pain Assessment in Clinical Trials (IMMPACT), which is a multidisciplinary group of pain researchers, government health officials, and other stakeholders. Core outcome domains recommended by IMMPACT include:

- Pain (including intensity, location, specific descriptors and qualities).
- Physical functioning (including ability to carry out activities of daily living, muscle strength and endurance, disease-specific measures).
- Emotional functioning (including distressed mood due to pain, including depression, anxiety, anger, and irritability).
- Participant ratings of global improvement and satisfaction with treatment (including participants' expectations about and satisfaction with treatment: whether the positive outweighs the negative attributes of the care).
- Symptoms and adverse events (including drug side effects, onset of new disease, addiction).
- Participant disposition (including starting with all patients screened, how many enrolled, how many dropped out, how many were lost to followup; includes reasons for not enrolling/dropping out, etc.).

Supplemental IMMPACT recommendations include:

- Role functioning (including work and educational activities; includes return to work).
- Interpersonal functioning (including relationships and activities with family, friends, and others).
- Pharmacoeconomic measures and health care utilization (including additional surgeries, care sought from a new provider, number of doctor or emergency room visits for pain).
- Biological markers (including assessments based on quantitative sensory testing, imaging, biopsy).
- Coping (see Boothby et al.52 for importance of coping concept in chronic pain).
- Clinician or surrogate ratings of global improvement (including assessments of treatment providers, spouse, etc.).
- Neuropsychological assessments of cognitive and motor function (including memory, executive function, reaction time).
- Suffering and other end-of-life issues.

(Adapted from IMMPACT consensus statement.53)

Figure 3 illustrates the number of studies that reported an outcome in each domain. In addition to the IMMPACT domains, we used one additional category, litigation and claims, that frequently recurred in the included studies. It covers whether the subject had any outstanding litigation or unresolved workers' compensation claims. The most frequently measured domain was physical functioning, with 70 percent of the studies reporting at least one physical functioning outcome. Almost as many studies reported a pain measure outcome. The single most frequently used measure was a visual analog scale (VAS). This is generally presented as a 10 cm line, with the ends labeled; if it were measuring pain intensity, the labels might be “no pain” and “the worst pain imaginable.” The person completing the VAS indicates where on the line his or her pain falls. The researcher or clinician then measures where the mark falls and reports it as the length of the line—for example, 50 mm for a mark halfway along the line. A VAS is often used to record pain intensity, but can also be used for other things: anxiety, pain interference with daily life, etc.

Figure 3 Outcome domains measured in included studies

Figure 3 is a bar chart with the number of studies that included at least one outcome from each of the outcome domains. 129 studies included at least one outcome measure of physical functioning; 123 studies included a pain outcome; 103 studies included an emotional functioning outcome; 89 studies included a role functioning measure; 89 studies included a pharmocoeconomic or health care use measure; 20 studies included a coping measure; 15 studies included a litigation or claims measure; 13 studies included participant ratings of global improvement and satisfaction with treatment; 12 studies reported symptoms and adverse events; 9 studies reported clinician or surrogate ratings of global improvement; 4 studies reported participant disposition; 4 studies reported interpersonal functioning; 2 studies reported neuropsychological assessments of cognitive and motor function; and 2 studies reported biological markers.

Followup periods for these studies were generally short, with 116 of the 183 studies reporting 0 to 6 months of followup; one-third of the studies (62) reported only before and after data—that is, there was no followup reported after discharge from the program. Ten studies reported followup periods of at least 36 months.

### Other Study Factors

Sample sizes in the included studies ranged from 1 (a case study) to 2730. The average sample size was 263. Several of the studies reported many participants lost to follow-up, particularly over longer tracking periods. The average loss to follow-up was 20 percent; the maximum was 87%, which was for the 12-month follow-up data point in a study with a large treatment cohort (748 began treatment).

This overview of the literature on MPPs suggests that a majority of the studies had no comparison population. In addition, the continuity or persistence of treatment effects is difficult to estimate based on existing studies because of large numbers of participants lost to followup and attrition.