# Background

## Chronic Noncancer Pain

Chronic pain symptoms cause major medical and socioeconomic problems and are the most common cause of long-term disability in middle aged people.1 The total estimated healthcare costs to Americans are more than $70 billion per year. Pain (of various types) is responsible for a half million lost workdays and costs more than $150 billion annually in health care, disability, and related expenses in the United States.2 The American Pain Society estimates that 9 percent of the U.S. adult population suffers from moderate to severe, noncancer related chronic pain.3 However, epidemiological research has suggested that the prevalence of chronic pain varies, depending on how the survey questions are asked and how chronic pain is defined. Researchers have estimated that from 10 to 20 percent of adults report having chronic pain when defined as persistent pain lasting at least 3 months.2 People who are 50 years of age and older are twice as likely to have been diagnosed with chronic pain when compared to people who are younger.2 Chronic pain management will gain greater public interest as the population ages, and continued research in this field will be an important investment for the future health care of aging Americans.

A widely accepted definition of pain was developed by the International Association for the Study of Pain: pain is “an unpleasant sensory and emotional experience associated with actual or potential tissue damage, or described in terms of such damage.”4 There is no single standard taxonomy of pain, but distinctions are frequently made between chronic and acute pain and between cancer and noncancer pain. Chronic pain is generally differentiated from acute pain by its duration, with chronic pain lasting longer than some specified time, often 3 or 6 months.5 Conditions that cause intermittent recurring pain, for example, migraine headaches or sickle-cell anemia, have characteristics of both chronic and acute pain.

## Current Medical Practice as Related to Management of Chronic Pain

There are currently no definitive cures for the most prevalent chronic pain syndromes, such as back pain, peripheral neuropathies, etc. The goal of chronic pain treatment has evolved from eliminating pain to managing pain to an extent that the patient's physical and emotional functioning is restored and overall quality of life improved. This is the model of care provided by the Multidisciplinary Pain Program (MPP).^i^ There is no single protocol for treatment provided in MPPs, but there is general agreement on some included methods. In addition, and in contrast to other types of pain treatment clinics, MPPs provide interdisciplinary care: providers from each of the components work together to develop the treatment plan. The definition used in this Technical Brief is based on the presence in the treatment in question of each of four components: medical therapy, behavioral therapy, physical reconditioning, and education. Further detail and examples of these components are provided in Appendix D.

i The MPP goes by many names in various literatures, including Interdisciplinary Chronic Pain Management (ICPM) and Interdisciplinary Pain Rehabilitation Programs (IPRPs). We chose MPP because it is more common.

Other treatment modalities used to treat the many aspects of chronic pain include:6

- Pharmacologic treatment, such as nonsteroidal anti-inflammatory drugs, acetaminophen, topical agents, antidepressants (including serotonin/norepinephrine reuptake inhibitors, and tricyclic antidepressants), anticonvulsants, and opioids. One or more of these medications may be indicated, for example, for arthritic, neuropathic or headache pain.
- Physical therapy, including both passive and active therapies.
- Occupational therapy.
- Behavioral/psychological/psychiatric therapy, including: pharmacological treatment for depression and anxiety, stress management training, relaxation training, cognitive behavioral therapy, operant therapy, and biofeedback.
- Vocational rehabilitation and disability management.
- Adjunctive treatment modalities, such as: transcutaneous electronic nerve stimulation; trigger point injections, including muscle injections with botulinum toxin (Botox^®^); prolotherapy; nerve blockade procedures, such as sympathetic block or epidural steroid injections; and acupuncture, and other complementary and alternative medical therapies.
- More invasive medical procedures, including: implantable intrathecal drug delivery systems, spinal cord and peripheral nerve stimulators, image-guided percutaneous spinal procedures, and surgery.

The multiplicity of treatment options has added complexity to health care decisionmaking for patients, providers, and payers. In addition, although there have long been guidelines and consensus opinion documents for treating acute and cancer pain, such guidance on therapy or combination of therapies for managing chronic noncancer pain has been less available.2

Chronic pain is neither adaptive nor self-limited. By definition, chronic, noncancer pain has continued past its usefulness—it continues to encourage rest and limits on movement when those limitations impair healing. It persists long enough that the patient may find that side effects and dependence on opioid painkillers limit quality of life. The pain is no longer a signal of new or impending tissue damage—it becomes a disease in itself, sometimes even after the original physical abnormalities are resolved.7,8 Chronic pain that continues after the apparent cause is gone is now thought to be a biopsychosocial phenomenon. Though no one knows exactly how the progression happens, it is thought to be influenced by factors such as acute pain intensity, depressive symptoms, and past trauma or stressful life events.7

The progression from acute to chronic pain is common: over 40 percent of people presenting in primary care for pain continue to experience pain a year later (Von Korff,9 quoted in Linton10). In the case of one disorder—low-back pain—approximately 90 percent of sufferers recover within 3 to 6 months (Mayer and Gatchel,11 quoted in Garofalo and Polatin12), leaving 10 percent experiencing chronic pain; the majority of those still experiencing pain after 6 months remain disabled after 1 and 2 years (Mayer,13 quoted in Garofalo and Polatin12).

When chronic pain does not fully respond to treatment, patients may be referred to a comprehensive treatment program such as an MPP, if one is available. However, not all chronic pain conditions follow this pattern of acute progressing to chronic pain. Fibromyalgia and some headache syndromes, for example, are not thought to be preceded by a musculoskeletal trauma or other acute event. Even so, these conditions are similar to other chronic pain conditions: they are characterized by patients exhausting more traditional forms of pain treatment, and their prognoses are believed to be influenced by psychological and social factors; for these reasons, conditions like fibromyalgia and chronic headache are believed to be amenable to treatment in the MPP model. The studies identified in this Brief include trials of multidisciplinary treatment of fibromyalgia,14-25 headache,17,26-30 and chronic widespread pain.15,23,31

This Technical Brief should add to the literature on MPPs by describing the current evidence base on this treatment modality, highlighting gaps in the evidence, and outlining the key issues facing patients and practitioners considering treatment options for chronic, noncancer pain.