# Included Studies

Table D-1 Study populations

Citation | MPP Population (duration of pain, prior treatments, etc.) | Comparison Population (duration of pain, prior treatments, etc.) | Clinical Conditions | Other Inclusion and Exclusion Criteria
Alaranta 1994 ^91^ | duration at least 6 months; one back surgery at most, no other recommended rehab, no contraindication for heavy exercise | same | back disease without inflammation | age 30-47, no compensation or claim of pension; exclusion: psychological reasons (serious AXIS I or II disorder of DSM III, low intelligence, neuropsychologic defects hindering patient from participating in the training program; lack of motivation including poor cooperation and unwillingness to perform the tests), severe back diseases contraindicating heavy, physical training (including primary need for operative treatment
Altmaier 1992 ^92^ | disabled and not working due to pain for 3-30 months | same | low back pain | not candidates for lumbar surgery; age 18-63; not currently involved in personal injury litigation; not in pain due to pregnancy, severe vertebral fracture, etc.; not demonstrating significant levels of depression or anger
Andary 1997 ^93^ | All pts received MPP treatment; no info given on definition of chronic pain, duration. “All diagnostic efforts, appropriate treatment, and pain control measures must have been exhausted or shown to be ineffective before initiation of the program” | | all patients completed chronic pain program; half were also treated for traumatic brain injury (TBI); the other half were matched controls with no sign of TBI
Angst 2006 ^18^ | history of failed or insufficient efficacy of outpatient treatment after at least 27 ambulatory PT sessions; 43% not working, 48% working part-time; 30% had disease duration of 0.8 to 4.9 years (remainder were more than 5 years) | | half had fibromyalgia, half had chronic back pain | failed outpatient treatment, FM or chronic back pain of at least 6 months duration; willingness to learn behavioral patterns and motivation to participate in graded activity exercise programs; ability to formulate realistic functional goals, sufficient cognitive abilities and German language skills to understand the content of the interventions, agreement/informed consent exclusion: severe somatic illness requiring specific treatment (e.g., cancer, inflammatory rheumatic disease, neurologic disease, post-surgery pain); manifest psychiatric disorder such as dementia, psychosis, suicidality
Angst 2009 ^21^ | 46% have “no working capacity”; 49% back pain, 32% FM, 18% widespread pain; mean duration of pain 72 months (range 6-156 months) | 34% have “no working capacity”; 73% back pain, 15% FM, 13% widespread pain; mean duration of pain 79 months (range 3-564 months) | back pain, fibromyalgia, widespread pain | inclusion: ability to complete self-assessment questionnaires, German language skills, written informed consent; additionally, MPP pts had to be willing to learn behavioral patterns and motivated to participate
Bailey 2003 ^94^ | pain lasting 6+ mos. | n/a | heterogeneous diagnoses | started with 162 consecutive referrals
Bendix 1998 ^95^ | 289 to 345 days of sick leave in the past 3 years; 38-39% work readiness; 33-35% participating in sports activity | 301 to 450 days of sick leave in the past 3 years; 16-45% work readiness; 19-33% participating in sports activity | disabling low back trouble: 47% with non-specific lumbago with or without sciatica | inclusion: 6 mos of disabling low back trouble, threatened job situation owing to back problems, aged 18 to 59, able to read and write Danish exclusion: current disk herniation (which might be amenable to surgery or bed rest), other surgically remediable lesions, inflammatory disease of the back, pregnancy, cancer, clinically relevant fractures; receiving social pensions; evidence of severe personality disorder or psychosis precluding participation in group treatment
Bendix 1995 ^81^ | median days of sick leave in 3 years: 296; 15% had previous back surgery; 23% work readiness | median days of sick leave in 3 years: 300 to 440 (depending on program); 17-32% had previous back surgery; 23-42% work readiness | disabling low back trouble | inclusion: 6 mos of disabling low back trouble, threatened job situation owing to back problems, aged 18 to 59, able to read and write Danish exclusion: current disk herniation (which might be amenable to surgery or bed rest), other surgically remediable lesions, inflammatory disease of the back, pregnancy, cancer, clinically relevant fractures; receiving social pensions
Bendix 1996 ^43^ | median days of sick leave in 3 years: 340; 16% had previous back surgery; 27% “could work” | median days of sick leave in 3 years: 370; 18% had previous back surgery; 16% “could work” | disabling low back trouble, “most” had a degenerative disease of the disk or facet or both | inclusion: 6 mos of disabling low back trouble, threatened job situation owing to back problems, aged 18 to 59 exclusion: current disk herniation (which might be amenable to surgery or bed rest), other surgically remediable lesions, inflammatory disease of the back, pregnancy, cancer, clinically relevant osteoporosis with or without fractures; receiving social pensions
Bendix 1997 ^79^ | median days of sick leave in 3 years: 273; 24% work readiness | median days of sick leave in 3 years: 300 to 415 (depending on program); 18-39% work readiness | disabling low back trouble: 44 to 50% with non-specific lumbago with or without sciatica | inclusion: 6 mos of disabling low back trouble, threatened job situation owing to back problems, aged 18 to 59, able to read and write Danish exclusion: current disk herniation (which might be amenable to surgery or bed rest), other surgically remediable lesions, inflammatory disease of the back, pregnancy, cancer, clinically relevant fractures; receiving social pensions
Bendix 1998 ^96^ | 41% work readiness; 240 days sick leave (median) in past 3 years; 42% active in sport | 28% work readiness; 323 days sick leave (median) in past 3 years; 27% active in sport | chronic disabling low back pain | inclusion: 6 mos of disabling low back trouble, threatened job situation owing to back problems, aged 18 to 61, able to read and write Danish exclusion: current disk herniation (which might be amenable to surgery or bed rest), other surgically remediable lesions, inflammatory disease of the back, pregnancy, cancer, clinically relevant fractures; receiving social pensions
Bendix 1998 ^97^ | 273 to 345 days of sick leave in the past 3 years; 37-38% work readiness; 35-38% participating in sports activity | 301 to 415 days of sick leave in the past 3 years; 16-46% work readiness; 24-32% participating in sports activity | disabling low back trouble: 44 to 53% with non-specific lumbago with or without sciatica | inclusion: 6 mos of disabling low back trouble, threatened job situation owing to back problems, aged 18 to 59, able to read and write Danish exclusion: current disk herniation (which might be amenable to surgery or bed rest), other surgically remediable lesions, inflammatory disease of the back, pregnancy, cancer, clinically relevant fractures; receiving social pensions
Bendix 2000 ^78^ | median 200 days of sick leave in the past 3 years; 53% work readiness | median 220 days of sick leave in the past 3 years; 40% work readiness | chronic low-back pain | inclusion: 6 mos of disabling low back trouble, threatened job situation owing to back problems, aged 18 to 59, able to read and write Danish exclusion: current disk herniation (which might be amenable to surgery or bed rest), other surgically remediable lesions, inflammatory disease of the back, pregnancy, cancer, clinically relevant fractures; receiving social pensions
Bliokas 2007 ^98^ | 4.0 years median pain duration; 45%-48% compensable injuries | 4.5 years median pain duration; 51% compensable injuries | 56.6% low back pain; 10.5% extremity pain | noncancer, nonarthritis pain; age less than 70 years; no primary drug and/or alcohol problem; no severe psychiatric conditions; able to read and speak English; willing and able to attend program; suitable for a group program (no poorly controlled anger, no imminent court proceedings, no planned significant medical interventions)
Buchner 2006 ^99^ | referred after failing standard biomedical therapy; mean duration of current pain was 16-17 months; 12-17% had prior surgery for the pain | | either chronic neck pain or chronic low back pain (39-45% of pts had pain radiating to an extremity) | age 18 to 55; 3+ mos duration of disabling pain that led to the pts being on sick leave for at least 6 weeks; exclusion: specific etiologies of the neck or lower back pain were excluded (e.g., tumor, trauma, inflammatory disease or infection, radicular sensorimotor deficits in upper or lower extremity), multiple major pain locations, main pain location other than neck or lower back
Buchner 2007 ^100^ | mean duration of pain 20 to 34 months (depending on age group); 11 to 19% had previous surgery due to low back pain; had disabling pain of at least 3 months duration that led to pts being on sick leave for at least 6 weeks (note: 64 to 71% of pts reported engaging in “regular daily sports activity” before treatment) | | chronic low-back pain | chronic low-back pain as the major symptom, age between 18 and 65, adequate command of “domestic language,” specific etiologies of the lower back pain were excluded (e.g., tumor, trauma, inflammatory disease or infection, nucleus pulposus prolapse with corresponding radicular pain, structural pathology of the lumbar spine), rheumatological disease, serious cardiopulmonary, vascular, or other internal medical conditions, any sensorimotor and/or neurological deficits in the lower extremity, spinal surgery in the year before admission to treatment, any other major pain location
Buchner 2007 ^101^ | all pts had disabling pain of at least 3 months duration that led to sick leave of at least 6 weeks; mean duration of pain 10 to 27 months (depending on chronicity group); 6 to 15% had previous surgery due to low back pain; 28 to 38% reported engaging in “regular sports activity” | | chronic low back pain | chronic low-back pain as major symptom, age between 18 and 65, adequate command of “domestic language,” specific etiologies of the neck or lower back pain were excluded (e.g., tumor, trauma, inflammatory disease or infection, radicular sensorimotor deficits in upper or lower extremity, severe degenerative changes, structural pathology of the lumbar spine), rheumatological disease, serious cardiopulmonary, vascular, or other internal medical conditions, any sensorimotor and/or neurological deficits in the lower extremity, spinal surgery in the year before admission to treatment, any other major pain location
Burnham 2010 ^23^ | mean pain duration 8.4 years; 31% employed | mean pain duration 8.1 years; 43% employed | MPP: 48% soft tissue pain (myofascial or FM), 34% mechanical spine pain, 18% neuropathic pain Pharma: 22% soft tissue, 35% mechanical spine, 29% neuropathic, 14% other | initial triage spinal vs. medical care--medical care triage for chronic pain complicated by significant medication management, psychosocial and/or comorbid medical illness issues; some medical triaged patients received consultation only (743 out of 825)
Burns 2000 ^102^ | benign MSK pain, average 23 months since injury, 55% underwent 1+ surgeries for pain, 70% receiving worker's compensation | | “benign musculoskeletal pain”: 59% low back pain | excluded for current alcohol/substance abuse, history of psychotic or bipolar disorders, could not read English, pain due to malignant condition or to migraine or tension headache
Burns 1998 ^103^ | benign MSK pain, average 24 months since injury, 55% underwent 1+ surgeries for pain, 70% receiving worker's compensation, 71% not working | | “benign musculoskeletal pain”: 62% low back pain | excluded for current alcohol/substance abuse, history of psychotic or bipolar disorders, could not read English, pain due to malignant condition or to migraine or tension headache
Burns 1998 ^104^ | benign MSK pain, average 23 months since injury, 55% underwent 1+ surgeries for pain, 71.3% receiving worker's compensation, 74.5% not working | | “benign musculoskeletal pain”: 66% low back pain | excluded for current alcohol/substance abuse, history of psychotic or bipolar disorders, could not read English
Burns 2003 ^105^ | average 40 months since injury, 49% had at least one pain related surgery, 58.5% not working due to pain | | benign MSK pain | excluded for pain due to malignant conditions (cancer, RA), could not read English, current alcohol/substance abuse, history of psychotic or bipolar disorder
Burns 2003 ^106^ | average 45 months since injury, 42% had at least one pain related surgery, 32.2% not working due to pain | | benign MSK pain | excluded for pain due to malignant conditions (cancer, RA), could not read English, current alcohol/substance abuse, history of psychotic or bipolar disorder
Burns 2005 ^107^ | average 32 months since injury, 49% had at least one pain related surgery, 58.5% not working due to pain | | benign MSK pain | excluded for pain due to malignant conditions (cancer, RA), could not read English, current alcohol/substance abuse, history of psychotic or bipolar disorder
Carleton 2010 ^108^ | average 4.9 previous insurance claims involving lost time from work; pain duration mean 1 year (range 3 mos. to 9 yrs); 78% employed prior to injury | | 50% low-back pain, 50% extremity pain (e.g., arm, shoulder, leg, knee) | medical clearance for participation
Cassisi 1989 ^109^ | average pain duration of 24 to 60 months, 49% had surgery prior to referral to the pain clinic (average of 1.3 surgeries per patient), 13% were employed | average pain duration of 24 to 60 months, 51% to 64% (depending on subgroup) had surgery prior to referral to the pain clinic (average of 1.1 to 1.7 surgeries per patient), 14% to 29% were employed | severe chronic low back pain | 4 comparison groups: pts whose participation was not approved by insurance, pts who declined participation, pts who participated in other programs, pts who began but dropped out of the UMCPRC program
Cedraschi 2004 ^16^ | mean duration of symptoms 8.4 years; 17% employed | mean duration of symptoms 9.5 years; 13% employed | Fibromyalgia | Inclusion: sufficient fluency in French to participate in group sessions, informed consent; Exclusion: presence of specific medical disorders which required immediate treatment, prevented physical activity or participation in swimming pool sessions
Chapman 1990 ^110^ | 36 to 60 months pain duration depending on subgroup, average of 1 surgery before referral | | low back pain | 15 pts excluded from study due to disagreement over whether pt showed inconsistency in behaviors and statements about pain (initial cohort of 175)
Chapman 1994 ^111^ | mean duration of pain is 85 months; 41% had previous back surgery, 41% had upcoming litigation or were receiving workers' comp | | chronic low back pain | fit into one of the MMPI clusters used in study (of 742 potential subjects, 558 did not fit the clusters)
Chapman 1996 ^112^ | chronic pain 3+ mos. duration; almost all had failed to obtain significant pain relief or normal function despite multiple previous treatments in health care settings; mean years since pain onset of 6.5 years for Center A, 4.6 years for Center B; 21.6% and 13.5% of patients were working at pretreatment; 59.5% and 73.6% were receiving disability at pretreatment | | variety, most frequent was low back pain
Chapman 2000 ^50^ | Pain duration of 3+ mos. despite having received “a variety of conventional medical approaches”; average duration of pain was 77.9 mos. for A, 57.0 for B and 26.7 for C | | chronic pain (variable location)
Ciechanowski 2003 ^113^ | significant pain-related disability; mean pain duration was 6.3 years; 30% working full- or part-time; 85% receiving pain-related disability compensation, 14% had litigation pending | | varied: 33% low-back pain; 21% neck, 19% shoulder or arm, 13% leg | age 18+; no current alcohol/substance abuse problem, no surgically remediable cause of pain, no comorbidity that would prohibit participation, no dementia; have pain interfering with patient's customary activities; have behavioral and functional goals; have funding for the program; able to read/write English
Connally 1991 ^114^ | suffering from chronic low back pain, candidate for lumbar sympathetic nerve blocks, no prior treatment with such blocks; average pain duration 5.8 years, average pain-related surgeries 1.5 | | chronic low back pain | willingness to participate
Cott 1990 ^115^ | mean duration of disability (i.e., on leave from work): 20.1 mos. (range 1-108 mos.); symptoms persisted for 6 mos.+; displayed marked illness behavior; medical and behavioral assessments indicated symptoms and severity of functional limitations inconsistent with level of identifiable pathology | | varied
Crisostomo 2008 ^116^ | Disabling low-back pain, not surgical candidates; average pain duration of 79 to 151 months, depending on subgroup; pre-admission, pts “received medical care from a physician and experienced incomplete symptomatic relief from multiple pharmacologic trials, repeated courses of physical therapy, or interventional pain procedures” | | chronic low-back pain | exclusion: fibromyalgia, inflammatory rheumatologic disease, pain related to previous malignancy
Currie 2003 ^15^ | non-cancerous chronic pain that has not responded to medical intervention; DSM-IV diagnosis of substance abuse or dependence | | comorbid chronic non-cancer pain and substance abuse; 61% MSK pain, 42% headache, 42% visceral pain, 20% FM; 66% opioid abusers; 16% alcohol and opioids | pseudoaddiction: drug-seeking behavior better explained by uncontrolled pain rather than true substance abuse
Davis 1992 ^117^ | Chronic pain patients who completed treatment program; mean duration of pain of 41.2 months, mean number of surgical procedures was 1.1 | | most common was low back pain | “found to be appropriate for the pain management program”
Deardorff 1991 ^73^ | mean duration of pain is 3 years; 43% had prior surgery, 60% were not working due to pain, 45% had ongoing litigation | mean duration of pain is 4 years; 27% had prior surgery, 47% were not working due to pain, 20% had ongoing litigation | varied: 55% of treated had low back pain (vs. 67% non-treated); 29% had head/neck pain (vs. 20% of non-treated) | no-treatment comparison group composed of those accepted to treatment program, but denied insurance authorization
Demoulin 2010 ^118^ | mean pain duration of 8.2 years for men, 12.6 years for women | mean pain duration of 7.8 years for men, 6.8 years for women | chronic low-back pain | exclusion: surgery within the past year, multiple surgeries, comorbidities including fibromyalgia and neck pain, medicolegal factors, severe initial pain precluding the evaluations or a large number of the exercises used in the treatment, psychological disturbances, obesity (BMI>30), age younger than 20 or older than 75
Dersh 2008 ^119^ | all had partial or total work disability for 4+ months; mean disability for non-Opioid Dependent pts was 17 months, for Opioid Dependent pts it was 29 mos.; 28% of non-ODD pts had had surgery before rehab vs. 49% of ODD pts; primary or secondary nonoperative care failed to overcome chronic disability; surgery had not produced resolution or was not an option; severe functional limitations remained | | Chronic Disabling Occupational Spinal Disorders | more than 4 mos. since work-related injury;
Doleys 1986 ^120^ | pain 6+ mos. duration, disability and pain complaints out of proportion with physical findings, unsuccessful treatment by conventional medical therapies; average pain duration of 30.2 months; 61% had undergone at least one surgical procedure, with an average of 2.4 | | 81% back pain, others arm, facial, elbow, knee, abdominal | no surgery within past 6 months, absence of surgical lesions, availability of spouse or significant other to participate in family meetings
Dunstan 2007 ^121^ | mean duration of pain was 31 months (range 6-162 mos.); mean time off work was 13.3 mos. (range 0-72 mos.); 33% were working at program commencement | | 63% back injury; all had work-related soft-tissue MSK injuries | age 18+; able to read/speak English; pain of 12+ weeks' duration preventing return to work or upgrading of duties; an Örebro Musculoskeletal Pain Questionnaire total score of ≥ 105; primary diagnosis is not mental disorder or addiction; serious medical conditions have been excluded as the source of symptoms.
Dysvik 2004 ^122^ | 20% working full or part-time; mean duration of pain was 10 years (range 1 to 46 years); 57% MSK pain | | chronic pain | 18-67 years old, chronic non-malignant pain for more than 6 months, medical investigation and/or treatment completed prior to referral, motivation to participate in an active rehab program, no ongoing litigation related to cause of pain
Dysvik 2005 ^123^ | 23% working full or part-time; pain duration: 23% of life; 51% MSK pain | | chronic pain; 51% with pain in several regions | 18-67 years old, chronic non-malignant pain for more than 6 months, medical investigation and/or treatment completed prior to referral, motivation to participate in an active rehab program, no ongoing litigation related to cause of pain
Edwards 2003 ^124^ | average pain duration 31-34 months, average previous surgeries 0.9 to 1.5 (women vs. men) | | chronic pain: 64% of men and 52% of women had low back pain | study looked only at treatment completers
Elkayam 1996 ^125^ | mean duration of symptoms 64 mos (range 3 to 120 mos) | | 67% lumbar pain, 18% cervical pain, 10% thoracic, 5% diffuse | age 22-60; back pain of 3+ mos duration; failure of previous physical therapy in Maccabi PT centers
Elkayam 1996 ^126^ | low-back pain duration of 3+ mos; failed physical and analgesic treatment; no previous spinal surgery, normal neurological examinations | | chronic non-progressive back pain in the lumbar region | age 22-60
Ersek 2008 ^127^ | pain 3+ months duration that interfered with daily activities; most common pain sites were Legs and/or Feet (72%), Back (53%), Buttocks/Hips (51%), and Shoulder (38%). | pain 3+ months duration that interfered with daily activities; most common pain sites were Legs and/or Feet (74%), Back (61%), Buttocks/Hips (58%), and Shoulder (46%). | chronic pain | age 65+; no surgery in past 6 mos., no surgery planned in next 6 mos.; living in a retirement community in the Puget Sound area of Washington state; no active cancer; able to complete study questionnaires
Evans 2001 ^128^ | | | chronic low-back pain
Feuerstein 1993 ^129^ | work disabled for 3+ months, receiving workers' comp indemnity and medical benefits | pts not eligible for the program for following reasons: 5 referred to other programs, 3 denied by insurance carrier, 3 refused by participant, 2 inappropriate for the program due to high level of illness behavior/depression/pain, 1 denied by employer, 1 denied by physician | nerve entrapment and tendonitis-related upper extremity disorders
Fishbain 2005 ^130^ | pain over 6 mos. duration, no info on prior treatments | | chronic low-back pain or chronic neck pain
Flavell 1996 ^131^ | approx 34% women; chronic pain more than 6 mos. | | chronic back pain | absence of behavioral problems which could interrupt the group process, acceptance of concept of pain management vs. cure; sufficient English language skills to understand the program
France 1991 ^132^ | mean duration of pain is 72.4 mos. (range 6 to 240 mos.); average number of pain operations was 2.5 (range 1 to 5) | | low back pain/sciatica | 6+ months daily pain, evidence of neurological dysfunction explaining location of pain, willingness to undergo pain mgmt under conditions of study; exclusions: dementia, schizophrenia, substance-use disorder, major neurological disorders, somatoform disorders, “evidence for overt secondary gains as obtained from history and psychiatric interview”
Fricton 1996 ^133^ | 6+ mos. duration (mean 102 months), has not responded to previous treatment; mean 3.5 different professionals consulted for the problem | | Chronic Temporomandibular Pain (TMJ or myofascial pain dysfunction)
Gagnon 2009 ^134^ | | chronic lower back pain | inclusion: more than 3 mos duration of pain, pain intensity above 50 mm on the VAS, pain has a “considerable” impact on patient's life (as measured by RDQ and DPQ); pain has mechanical characteristics without inflammatory symptoms; normal neuro exam; absence of predominant radicular pain (sciatic or crural) exclusion: symptomatic back pain (spondylitis or tumor); major psychological issues | directed by physicians
Garcy 1996 ^135^ | minimum 4 months post-injury; “‘worst-case’ regionally selected and referred Chronic Disabling Spinal Disorder patients” | | Chronic Disabling Spinal Disorder
Gatchel 1986 ^136^ | minimum 4-months post-injury; need for subsequent surgery ruled out; referred as “failures of conventional medical/surgical care”; avg. months since injury=23.8; avg. months since last working =12.5; percent with prior surgeries = 39.5 | | chronic low-back pain
Gatchel 1986 ^137^ | minimum 4-months post-injury; need for subsequent surgery ruled out; referred as “failures of conventional medical/surgical care”; avg. months since injury=23.8; avg. months since last working =12.5; percent with prior surgeries = 39.5 | | chronic low-back pain
Gatchel 1994 ^138^ | average ∼14 mos. since injury; referred “because they had not responded to conventional/surgical care” | | Chronic low back pain disability | at least 4 mos. since injury, speak English, reasonable surgical alternative determined to be unnecessary by 2 or more physicians
Gatchel 1999 ^139^ | minimum 4 months post-injury | | chronic spinal disorders
Gatchel 2002 ^140^ | average 86.6 months | | multiple heterogeneous | pt has persistent pain limiting work/other activities; surgery didn't work/wasn't clinically indicated; English speaking; for those with insurance, payer authorized treatment; pt agreed to complete prescribed treatment program
Gatchel 2005 ^141^ | minimum 4-months post-work-related injury; primary or secondary nonoperative care failed to overcome chronic disability; surgery had not produced resolution or was not an option; severe functional limitations remained | | chronic disabling work-related spinal disorder (CDWRSD) | able to speak English or Spanish, consented to and began prescribed functional restoration
Gatchel 2009 ^90^ | pain duration 68 mos.; 77% Air Force; 83% enlisted (vs. officer) | pain duration 63 mos.; 72% Air Force; 80% enlisted (vs. officer) | musculoskeletal disorder (70-75% lumbar) | active duty military with at least 18 months retainability (to ensure availability for follow-up); no Medical Evaluation Board in progress; decreased ability to perform duty requirements because of pain and disability; no current plan for surgery, morphine pump, or spinal cord stimulator
Gatchel 2010 ^142^ | minimum 4-months post-work-related injury; primary or secondary nonoperative care failed to overcome chronic disability; surgery had not produced resolution or was not an option; severe functional limitations remained | | chronic disabling occupational spinal disorders (CDOSD) | able to speak English or Spanish, consented to and completed prescribed functional restoration
Glenn 2003 ^143^ | average 32 months since injury, 49% had at least one pain related surgery, 58.5% not working due to pain | | benign MSK pain | excluded for pain due to malignant conditions (cancer, RA), could not read English, current alcohol/substance abuse, history of psychotic or bipolar disorder
Gross 2005 ^144^ | median 86-92 days between injury and admission, average 183-240 days between injury and admission; all WCB-Alberta claimants receiving time-loss benefits for conditions related to the low back of at least 6 weeks duration; typically those admitted to this program are continuing to experience disabling back pain beyond expected recovery times, have not returned to work following a period of primary care management, not requiring further medical investigation | | disabling low-back pain
Guck 1988 ^145^ | pain duration 6+ mos.; “other medical or psychiatric treatments were not more appropriate” | | pain of a chronic benign nature (“that is, it was not the result of an active disease process”) | pts indicated “that they wanted to participate in the program”, pts “agreed to involve family members or significant other persons in treatment”
Guck 1999 ^80^ | pain duration 6+ months interfering significantly with activities of daily living | | chronic nonmalignant pain | exclusion: presence of surgically correctable condition, presence of coexisting medical problem that would preclude ability to do the required physical exercises (e.g., diabetes, cardiac disease, etc.); presence of organic brain syndrome or psychosis; age under 16; inability to read/write English
Gunreben-Stempfle 2009 ^28^ | for patients with migraine, 13% had been experiencing headaches for less than 5 years, 7% for 5 to 10 years, and 80% for more than ten years; for patients with Tension-Type Headaches, 22% had been experiencing headaches for less than 5 years, 15% for 5 to 10 years, and 63% for more than ten years | for patients with migraine, 3 or 14% had been experiencing headaches for less than 5 years, 13 or 20% for 5 to 10 years, and 84 or 66% for more than ten years (first number is for low-intensity pain program participants, second number is for primary care patients); for patients with Tension-Type headaches, 45 or 52% had been experiencing headaches for less than 5 years, 14 or 24% for 5 to 10 years, and 41 or 24% for more than ten years (first number is for low-intensity pain program participants, second number is for primary care patients) | chronic headache: Migraine and/or Tension-Type Headaches | age 18+, headaches for at least 1 year and diagnosed as either migraine and/or tension-type headache or other headache disorders according to the criteria of the International Headache Society, occurring on 8 or more days per month; excluded if not able or willing to complete the questionnaires or sign the informed consent form
Gustafsson 2002 ^13^ | mean years of symptoms: 13.2; 48% diagnosed as FM | mean years of symptoms: 12.5; 70% diagnosed as FM | Fibromyalgia or widespread chronic pain | well-analyzed pain not caused by injury or other diseases, no misuse of drugs or serious psychiatric disease, considered by the social insurance office to need rehabilitation for return to work
Hatten 2006 ^146^ | mean for entire sample was 93 months; mean for MPP was approx 99 mos. | mean for entire sample was 93 months; mean for non-MPP was approx 82 mos. | chronic spinal pain (cervical, lumbar or thoracic) | consecutive sample of pts with primary diagnosis of chronic spinal pain seen at center for whom billing information was available; protocols determined by treating physician's clinical judgment and managed care coverage rules; exclusion: terminal illness
Hazard 1989 ^147^ | 4+ months continuous disability from work because of back pain (avg. 19 mos.), avg. 0.4 spinal surgeries | 4+ months continuous disability from work because of back pain (avg. 19 mos.), avg. 0.4 spinal surgeries | chronic disabling low-back pain | no evident surgically remediable lesion, no evidence of psychosis or severe personality disorder precluding participation in group treatment
Hazard 1991 ^148^ | average 14.7 mos. work loss; avg. 21.6 mos. pain duration, avg. 0.3 spinal surgeries | 4+ months continuous disability from work because of back pain (avg. 19 mos.), avg. 0.4 spinal surgeries | chronic disabling low-back pain | no evident surgically remediable lesion, no evidence of psychosis or severe personality disorder precluding participation in group treatment
Hazard 2009 ^149^ | 3+ months disabling back pain (avg. 19 mos.), avg. 0.4 spinal surgeries | 4+ months continuous disability from work because of back pain (avg. 19 mos.), avg. 0.4 spinal surgeries | chronic disabling low-back pain | no evident surgically remediable lesion, no cardiovascular comorbidity restricting activity, no evidence of psychosis or severe personality disorder precluding participation in group treatment, treadmill, lifting, flexibility tests indicating significant deficits compared to pts personal functional goals
Hildebrandt 1997 ^150^ | mean duration 153 months; 30% had prior back surgery; 81% not working (receiving full work compensation, mean duration of time off was 9 months) | | chronic low back pain | age 18-57, chronic back pain not a result of inflammation or cancer, no indication for surgical treatment, at least 3 months of time off work during the last year
Hooten 2007 ^19^ | persistent (mean 9.9 years) non-cancer pain and associated functional impairment; pre-admission, pts “received medical care from a physician and experienced incomplete symptomatic relief from multiple pharmacologic trials, repeated courses of physical therapy, and interventional pain procedures” | | Fibromyalgia
Hooten 2009 ^151^ | average 89 to 149 mos. pain duration depending on subgroup; pre-admission, pts “received medical care from a physician and experienced incomplete symptomatic relief from multiple pharmacologic trials, repeated courses of physical therapy, or interventional pain procedures” | | multiple diagnoses | exclusion: pts who used forms of tobacco other than cigarettes
Hooten 2009 ^152^ | average 103 to 144 mos. pain duration depending on subgroup; pre-admission, pts “received medical care from a physician and experienced incomplete symptomatic relief from multiple pharmacologic trials, repeated courses of physical therapy, or interventional pain procedures” | | multiple diagnoses | exclusion: pts who used forms of tobacco other than cigarettes, pts with pain of <3 month duration, major surgery within 6 mo
Howard 2009 ^153^ | minimum 3 months post-injury; primary or secondary nonoperative care failed to overcome chronic disability; surgery had not produced resolution or was not an option; severe pain and functional limitations remained | | CDOMD | able to speak English or Spanish
Huge 2006 ^154^ | mean duration of pain 10.3 years; median duration 6 years; 36% had prior surgery | mean duration of pain 6.9 years; median duration 6 years; 26% had prior surgery; accepted for treatment program, but did not participate due to problems concerning occupational situation or remoteness of residence | Chronic low-back pain | able to be matched with a control (41 treatment and 38 control patients completed questionnaires, 22 pairs were created); chronic low-back pain for at least 12 weeks, good cardiopulmonary capacity, ergometry with at least 100 W and no signs of change in ECG, no contraindication for physical therapy, no signs of inflammatory or rheumatic causes of back pain, no fibromyalgia, no malignant disease, no major segmental instability as cause of chronic back pain, no claim for workers compensation or disability pension
Jensen 1995 ^155^ | mean 256 days sick-list in year prior to treatment | mean 237 days sick-list in year prior to treatment | chronic neck and shoulder pain | no objective neurological signs, age 20-55, fluent in Swedish, no comorbidity that could impair participation (e.g., heart condition, alcoholism)
Jensen 1994 ^156^ | 74% workers comp claim, 37 months mean duration of pain; 83% mixed back and neck pain | 66% workers comp claim, 44 months mean duration of pain; 80% mixed back and neck pain | non-specific pain syndrome in neck or back | age 20-55, non-specific pain syndrome without objective neurological signs, fluent in Swedish, currently employed, sicklisted for six months or less
Jensen 1998 ^157^ | neck/shoulder pain: 76%; 51% pending insurance claim; mean pain duration in weeks: 44; mean sick-leave during 6 months before inclusion: 81 days | neck/shoulder pain: 69%; 40% pending insurance claim; mean pain duration in weeks: 47; mean sick-leave during 6 months before inclusion: 78 days | non-specific pain syndrome in neck or back | age 20-55, non-specific pain syndrome without objective neurological signs, fluent in Swedish, currently employed, sicklisted for six months or less
Jensen 1992 ^158^ | 74% unemployed due to pain; 58% receiving financial compensation due to pain; average duration of pain 4.98 years (range 2 months to 32 years) | | chronic pain: 47% low back, 13% lower extremities, 11% head, 11% neck, 10% shoulders/arms
Jensen 1994 ^159^ | mean pain duration = 5.26 years (range 3 months to 32 years); 16% working full- or part-time; 16% had active litigation pending regarding pain | | varied: 46% low back pain, 15% head, 13% leg, 10% neck | age 18-65; no current alcohol/substance abuse problem, no surgically remediable cause of pain, no comorbidity that would prohibit participation, no dementia; have pain interfering with patient's customary activities; have behavioral and functional goals; have funding for the program; able to read/write English
Jensen 2001 ^160^ | significant pain-related disability; median pain duration was 3.2 years (range 4 months to 48 years); 29% working full- or part-time; 60% receiving pain-related disability compensation, 12% had litigation pending | | varied: 34% low-back pain; 18% neck, 13% shoulder or arm, 12% leg | age 18-65; no current alcohol/substance abuse problem, no surgically remediable cause of pain, no comorbidity that would prohibit participation, no dementia; have pain interfering with patient's customary activities; have behavioral and functional goals; have funding for the program; able to read/write English
Jensen 2003 ^14^ | UW: pain duration mean 5.9 years, range 7 months to 48 years FM: pain duration mean 8.7 years, range 8 months to 64 years | | UW: 31% low-back pain, 17% upper extremity, 16% neck pain, 15% lower extremity FM: Fibromyalgia | none noted
Jensen 2004 ^17^ | UW: pain duration mean 6.3 years, range 7 months to 48 years FM: pain duration mean 7.5 years, range 6 months to 64 years | | UW: 30% low-back pain, 17% upper extremity, 16% neck pain, 15% lower extremity FM: Fibromyalgia | FM: excluded for medically treatable illnesses accounting for symptoms, unable to participate in PT due to medical condition, had severe psychological disorders (psychoses, severe major depression), unable to read/write English
Jensen 2007 ^161^ | median pain duration of 3.2 years (range 4 months to 48 years); 29% working full- or part-time; 60% receiving pain-related disability compensation; 12% had litigation pending | | varied: 34% low-back pain; 18% neck, 13% shoulder or arm, 12% leg | age 18-65; no current alcohol/substance abuse problem, no surgically remediable cause of pain, no comorbidity that would prohibit participation, no dementia; have pain interfering with patient's customary activities; have behavioral and functional goals; have funding for the program; able to read/write English
Jousset 2004 ^162^ | presently engaged in a non-limited work contract, but threatened in their job situation by chronic low back pain; 47% on sick leave; mean 195 days of sick leave in the 2 previous years; 35% with previous surgery | presently engaged in a non-limited work contract, but threatened in their job situation by chronic low back pain; 51% on sick leave; mean 202 days of sick leave in the 2 previous years; 15% with previous surgery | chronic low back pain | age 18-50, living in 3 counties in west of France, pain not relieved by medical or surgical interventions; exclusion: pain of specific origin, spinal surgery within past 4 months, cardiac or respiratory abnormalities after exercise stress tests, psychiatric disorders precluding group participations, receiving disability pensions, not motivated or refused to participate
Kaapa 2006 ^163^ | mean pain duration of 16 mos; 48% engaged in leisure time physical activity at least 2 times per week | mean pain duration of 14 mos; 54% engaged in leisure time physical activity at least 2 times per week | chronic low-back pain with or without sciatica | age 22-57, employed in health and social services; included only women (initial pool included only 2% men); at least 12 months of pain, experienced daily or near-daily, positive attitude of “the superiors” (assumed to be supervisor/boss) exclusions: clinical symptoms suggesting acute disc prolapse accompanied by nerve root entrapment (within 3 mos), back surgery in past 6 mos, severe cardiovascular or other disorder interfering with active rehab, specific back disorder, severe mental illness (psychosis or severe depression), more than 90 days off work due to LBP during preceding year, pension in near future (within 2 years), pregnancy, ongoing or planned low back pain rehabilitation
Kenny 2004 ^164^ | mean pain duration of 38 to 74 months (depending on subgroup) | | chronic pain
Keogh 2005 ^165^ | 72% not working due to pain; mean pain duration of 146.7 mos (range 16 to 685 mos) | | multiple: “chronic pain syndrome” | 6+ mos pain duration, no known psychiatric conditions that would interfere with the intervention
Kidner 2009 ^166^ | disability more than 4 months post-injury, lack of response to previous surgery/nonsurgical treatments, severe impairment of physical functioning | | chronic disabling occupational musculoskeletal disorders | opioid status (taking opioids vs. not currently taking opioids) at start of treatment could be determined; speak English or Spanish
Kleinke 1988 ^167^ | mean duration of pain 8.4 years (range 1 to 36 years); mean number of back surgeries was 1.2; 41% were unemployed because of chronic pain | | chronic back pain
Kohles 1990 ^168^ | average 10+ months since last worked | | Chronic lower back pain | prior spinal fusion
Kole-Snijders 1999 ^169^ | mean pain duration of 9.8 years (range 10 mos to 40 years); 79% receiving disability compensation (mean duration 3.7 years); 39% received back surgery, 28% used supportive equipment for ambulation; comorbidities included 40-46% with phobias, 30% with depressive disorder | included in figures for MPP population | low-back pain | inclusion: age 18-65, 6+ mos low-back pain, discrepancy b/w objective findings and pain complaints, cooperation of spouse/relative/close friend to participate in weekly spouse training; exclusion: illiteracy, pregnancy, involvement in litigation concerning social disability income, alcohol or drug abuse, serious psychopathology (e.g., antisocial personality disorder, psychosis, or organic brain damage), specific medical disorders requiring medical treatment or rendering patients unable to participate in program
Koopman 2004 ^170^ | mean complaint duration 76.5 mos., mean absence from work 12.2 mos. | | Lower back pain for 6+ mos. | inclusion: age 20-60, unsatisfactory results with prior treatment, sufficiently motivated to participate, some positive expectation for return to work after program, approval of insurance company and employer; exclusion: presence of a progressive illness, mental disorder, or low intelligence (defined as less than primary school and 3 years of secondary education and inability to complete the questionnaires), inability to travel
Lang 2003 ^171^ | median pain duration of 12 years, 47% low-back pain, 53% low-back and leg, 26% low-back and leg below knee; 18% had previous lumbar surgery | median pain duration of 9 years, 43% low-back pain, 57% low-back and leg, 32% low-back and leg below knee; 22% had previous lumbar surgery | chronic low back pain | inclusion: seeking treatment of pain in the lumbar and/or thoracic spine with facultative irradiation cranially, caudally or ventrally, persistence of pain for at least 3 months without decreasing intensity and no need for surgical intervetion. exclusion: did not give informed consent, not able to answer questionnaires independently, pain was localized over almost the whole body or history of cancer
Law 2009 ^172^ | mean duration of pain 6 years | | 77% back pain, 53% leg pain, 40% arm pain | pain of MSK origin persisting 3+ mos.; over 18 years; excluded if unable to tolerate testing procedure, had excessive hamstring muscle extensibility, required further medical, surgical, or psych investigations or interventions, had a history of drug or alcohol abuse
Lipchik 1993 ^48^ | chronic nonmalignant pain of 6+ mos. duration | same | chronic nonmalignant pain | no evidence of dementia or active psychosis, able to participate in active physical rehab, motivated to participate (as evidenced in evaluation interview)
Luoto 1996 ^173^ | at least 6 mos of chronic low back pain which had caused trouble in work and everyday life and had not reacted favorably to the outpatient physiotherapy | healthy volunteers with no musculoskeletal disorders in the previous 12 months | chronic low-back pain | aged 20-60 exclusions: LBP requiring immediate surgery, a heart or circulatory disease that would prevent them from undergoing an intensive rehabilitation, a psychiatric disorder that might interfere with the rehabilitation
Luoto 1998 ^174^ | average duration of lower-back pain was 12.1 years for men with moderate LBP, 7.8 years for women with moderate LBP, 8.8 years for men with severe LBP, and 13.5 years for women with severe LBP | healthy volunteers with no musculoskeletal disorders in the previous 12 months | chronic low-back pain | aged 20-60 exclusions: LBP requiring immediate surgery, a heart or circulatory disease that would prevent them from undergoing an intensive rehabilitation, a psychiatric disorder that might interfere with the rehabilitation
Lynch 1996 ^175^ | chronic nonmalignant pain of 6+ mos. (mean 45 months) duration referred for “consideration of outpatient pain management as a treatment option” | chronic nonmalignant pain of 6+ mos. (mean 34 months) duration referred for “consideration of outpatient pain management as a treatment option” | variety
Maclaren 2006 ^176^ | average time since injury was 22.8 months, most patients had undergone no surgeries (average 0.43, range 0 to 8); all participants were receiving worker's compensation benefits; at completion of treatment, 61% had a job available to return to at prior employer | | 72% low back pain, 17% neck and shoulder
Magnusson 2004 ^27^ | Chronic Daily headache for at least 6 mos. | Transformed migraine (very frequent, often daily, migraine) | headache | MPP: no ongoing headache-related litigation or Work Comp claim, no disabling medical or psychiatric condition Pharma: willingness to sign informed consent
Man 2007 ^177^ | median pain duration 46 months (range 12-333 mos.) | | 58% back pain, 22% limbs | chronic pain 3 mos.+, no progress in rehab despite treatment, no further option for medical or surgical treatments, reliance on medication and other aids, distress and disability due to the pain, no active major psycho disorder or primary addiction problem, no severe physical impairment, no literacy/language difficulty, agreement and commitment to participate in the programme
Mangels 2009 ^178^ | 65 to 68% married; chronic back pain | 67% married; chronic back pain | back pain, musculoskeletal disease (ICD-10 M00-99) | insurant at the Deutsche Rentenversicherug Bund, able to understand German; exclusion: surgery during the previous 3 months, intended treatment period of less than 3 weeks due to personal or hospital reasons, unexpectedly short admission process hindering the randomization process
Maruta 1990 ^179^ | mean duration of pain is 80 months; most had received multiple treatment types (medication, surgery, PT, traction, body casts, nerve blocks, psychotherapy, hypnosis, etc.); 43% were receiving disability compensation | | multiple diagnoses | inclusion: treatment completers; exclusion: “lack of motivation to participate,” related malignant disease, litigation in progress
Masuda 2005 ^40^ | mean duration of illness 45 mos., mean number of hospitalizations 12.4 | | somatoform pain disorder
Mayer 1994 ^180^ | 6+ mos. post injury; evaluated to rule out the need for additional or primary surgery | | chronic low-back pain | excluded for incomplete test data, lumbar fusion, multiple surgeries, diagnoses involving more than purely lumbar disorders
Mayer 1998 ^75^ | (all pts treated with MPP, some additionally had either discectomy or fusion) minimum 4 mos. post-injury; all appropriate surgical or injection procedures had been performed or refused | | chronically disabled patients on workers' compensation for injury | all workers' comp pts who had completed MPP b/w 1989 and 1993 were assessed for inclusion; all with either discectomy alone or spinal fusion were selected for inclusion; matched non-surgical controls were selected for each surgical pt
Mayer 2001 ^181^ | none working full-time, less than 10% performing any light or part-time work; minimum 4-mos partial/total disability since work-related injury; failure of prior primary/secondary nonoperative care, failure to respond to surgical treatment (if indicated) persistence of severe functional and psychosocial barriers to recovery with ongoing health care seeking behaviors | | Chronic Disabling Spinal Disorder | treatment completers only
Mayer 2006 ^182^ | minimum 3 mos. partial/total disability since work-related injury; failure of prior primary/secondary nonoperative care, failure to respond to surgical treatment (if indicated); persistence of severe functional and psychosocial barriers to recovery | | chronic occupational spinal disorders | English or Spanish speaking or translation available
Mayer 1986 ^183^ | referred “as failures of conventional medical/surgical care”; avg. 23.8 mos. since injury; avg. 11.6 mos. since last working | “nearly identical” to PRIDE group | chronic low back pain | authorized by insurance carrier
Mayer 1987 ^184^ | approx 25 mos. post-injury; avg. 1 surgeries; “referred as failures of conventional medical/surgical care” | avg. 21 mos. since injury; avg. 1 surgeries; “referred as failures of conventional medical/surgical care”; comparison group created as pts denied coverage by responsible insurance carrier, “almost always because of a negative policy toward ‘pain clinics’; invariably a matter of policy throughout a company rather than a punitive measure directed specifically at an individual patient” | industrial low back injury
Mayer 1988 ^185^ | approx 12 mos. since injury; “perception of previous treating physicians that the persistently disabled patient had failed prior therapeutic efforts” | | chronic low-back and/or cervicothoracic disorders
Mayer 2002 ^186^ | 4+ mos. post-injury; surgical treatment ruled-out (Except the 52 surgical pts, who underwent anterior cervical fusion at one or two levels before referral to MPP) | | cervical spine disorders | treatment completers only
Mayer 2008 ^187^ | average 15.5 months of disability; minimum 4-mos partial/total disability since work-related injury; failure of prior primary/secondary nonoperative care, failure to respond to surgical treatment (if indicated); persistence of severe functional limitations | | Chronic Disabling Occupational Spinal Disorders
McCracken 2005 ^188^ | 89% receiving national wage replacement or financial benefit; 9.8% were doing any work outside the home; mean pain duration of 132.5 mos (range 12 to 528 mos); had previously seen an average of 6.3 different physicians about their pain, though 2% had never obtained previous, specialist medical consultation and treatment; 43.3% had prior surgical treatment for pain | | multiple: “chronic pain syndrome”; pain-related distress and disability; 50% low back pain; 14% lower limb, 12% upper limb, 11% neck; 71% multiple sites | 3+ mos pain duration, were not appropriate for further medical tests or invasive procedures, agreed with treatment purpose, had no known psychiatric conditions that would interfere with the intervention
Michaelson 2004 ^189^ | 47% on full sick leave (another 20% on partial sick leave); mean pain duration 106 mos | | low back or neck pain | exclusions: neurologic diseases, signs of brain damage, rheumatic and psychiatric diagnoses, younger than 18, older than 65, minimum pain intensity of 25 out of 100 on a VAS, pain for more than 6 mos prior to treatment
Middaugh 1988 ^190^ | mean duration of pain 55 to 60 mos.; mean number of surgeries 0.9 to 1.4 | | multiple: 76% of older pts and 85% of younger pts had back and neck pain | inpatient vs. outpatient determined by: distance from hospital, medication level, funding, and activity level/degree of disability
Mohler 1991 ^191^ | diagnosed with craniomandibular disorder; all but one had multiple pain complaints involving neck, shoulder, back, arm, or leg; mean pain duration 30 months (range 4 mos. to 8 years) | | chronic craniomandibular disorder | non-carcinogenic pain, duration 4+ mos., identified need for 2 or more multidisc services in PT, OT, psychology, and/or dentistry
Moore 1986 ^24^ | Male, 95% unemployed, 87% receiving disability compensation; average duration of pain was 14.2 years, average number of prior surgeries for pain was 3.5 | | chronic pain; 53% Lower back pain, 17% headaches
Norrefalk 2005 ^192^ | 34% generalized pain or FM, 19% generalized neck and back pain, 19% cervicobrachialgia, 13% low back pain; mean absence from work 22 mos; none working at start of program; referred after all other treatments and rehab attempts had failed | 43% generalized pain or FM, 29% generalized neck and back pain, 14%whiplash; mean absence from work not reported; none working at start of program | chronic pain | relevant medical and surgical treatments completed prior to referral; excluded: employed, weak knowledge of Swedish language (though interpreters were used when needed), pts with ongoing drug, narcotics, or alcohol abuse
Norrefalk 2006 ^193^ | 34% generalized pain or FM, 19% generalized neck and back pain, 19% cervicobrachialgia, 13% low back pain; none working at start of program; referred after all other treatments and rehab attempts had failed | | chronic pain | relevant medical and surgical treatments completed prior to referral; excluded: employed, weak knowledge of Swedish language (though interpreters were used when needed), pts with ongoing drug, narcotics, or alcohol abuse
Norrefalk 2007 ^194^ | referred to pain program “since every other intervention or rehabilitation measure had failed”; at least 3 months on sick-leave prior to rehab (mean = 17 mos., median = 20 mos.) | median absence from work = 19 mos.; selected from an unrelated study conducted at the Rehabilitation Centre and run by the National Swedish Insurance Board; selection criteria: performed evaluation at the same period of time as the study group concluded the rehab program, long-term follow-up information available on return-to-work, on sick leave at time of evaluation, of working age, has “long lasting pain” as main diagnosis | multiple diagnoses | only pts on sick leave included (less than 2 h per day); excluded from intervention program for inadequate knowledge of Swedish language (interpreters were used when needed), ongoing drug/narcotic/alcohol abuse, major cognitive deficit
Norrefalk 2008 ^195^ | mean 22 months sick-leave before treatment | mean 19 months sick-leave before assessment; matched pair-wise with treatment group on age, gender, origin, and time on sick-leave | chronic pain | relevant medical and surgical treatments completed prior to referral; excluded: employed, weak knowledge of Swedish language (though interpreters were used when needed), pts with ongoing drug, narcotics, or alcohol abuse
Olason 2004 ^196^ | 49% had pain duration of more than 5 years, 38% one to four years duration, 13% less than 1 year; 18% working at admission | | 48% low-back pain, 29% post-traumatic pain, 23% “other” | over 3-yr period, pts undergoing treatment at program were randomly selected to participate in study (i.e., respond to the questionnaires); no other inclusion/exclusion criteria reported
Patrick 2004 ^197^ | disabled and not working due to pain for 3-30 months | same | low back pain | not candidates for lumbar surgery; age 18-63; not currently involved in personal injury litigation; not in pain due to pregnancy, severe vertebral fracture, etc.; not demonstrating significant levels of depression or anger
Perry 2010 ^77^ | mean duration of pain of 66.9 mos.; 39% quadriplegia, 61% paraplegia; 42% unemployed | mean duration of pain of 53.4 mos.; 40% quadriplegia, 60% paraplegia; 50% unemployed | Spinal Cord Injury-related chronic pain | over 18, having SCI with permanent neurologic deficit and persistent pain of 3 mos. duration or longer; exclusion: inadequate command of English to complete questionnaires, current presence of a psychotic disorder, TBI sufficient to interfere with participation in a pain management program
Pfingsten 1997 ^74^ | mean duration 150 months; 30% had prior back surgery; mean of 6.3 weeks of inpatient treatment in the 2 years prior to treatment; 81% not working (receiving full work compensation, mean duration of time off was 9 months) | | chronic low-back pain | not described
Polatin 1989 ^198^ | average time since injury 15-36 months (depending on subgroup) | | chronic low-back pain | 4 comparison groups selected from all who completed pre-treatment assessment: PRIDE treatment completers who 1. were employed 1 year later, or 2. were not employed 1 year later, 3. drop outs from the PRIDE treatment program, 4. pts recommended for treatment who did not enter the program
Polatin 1997 ^199^ | average 18 mos. disability before program; primary and secondary nonsurgery care failed to resolve disability and pain; (further) surgery determined to be unnecessary by 2 or more physicians | | chronic low back pain
Proctor 2004 ^200^ | average 17.8 mos. disability before program; before rehab, >95% were totally disabled, none were working full-time; work-related injury 4+ months before study; primary and secondary nonsurgery care failed to resolve disability and pain; surgery had not resolved problem or provided relief or was not an option; severe functional limitations remained | | chronic disabling occupational musculoskeletal disorders (CDOMD) | MSK injury claim without adequate recovery; speak English or Spanish
Proctor 2005 ^201^ | average 19 months since injury; work-related injury 4+ months before study; primary and secondary nonsurgery care failed to resolve disability and pain; surgery had not resolved problem or provided relief or was not an option; severe functional limitations remained | | chronic disabling occupational musculoskeletal disorders (CDOMD) | speak English or Spanish
Protas 2004 ^202^ | average time since injury 14-16 months (depending on subgroup); all had participated in secondary physical therapy before referral to this MPP for failure to return to work or severe ongoing pain complaints | | chronic work-related spinal disorders | treatment completers only; exclusion: pts taking medication limiting heart rate response, pts not treated for a cervical or lumbar disorder
Rainville 1992 ^203^ | average 17 mos. since injury; 19% prior back surgery | | chronic low back pain | age 18-70, absence of surgically correctable lesion as the cause of pain or pt refusal of surgery; absence of spinal fracture, infection, or cancer as etiology of pain; absence of significant disability from other medical conditions; disability from full-time, full-duty work because of pain; reading and writing comprehension of English
Rainville 1993 ^204^ | average 17 mos. since injury; 19% prior back surgery | average 22 mos. since injury; 13% prior back surgery | chronic low back pain | age 18-70, absence of surgically correctable lesion as the cause of pain or pt refusal of surgery; absence of spinal fracture, infection, or cancer as etiology of pain; absence of significant disability from other medical conditions; disability from full-time, full-duty work because of pain; reading and writing comprehension of English
Robbins 2003 ^38^ | not reported | not reported | “heterogeneous sample of chronic pain diagnoses” | 201 patients started the program, 127 successfully completed; major reason for dropping out (78%) was program noncompliance; of 127 successful completers, 65 were reached for 1-year follow-up; of the 65, 9 were early graduates because of significant progress at midpoint evaluation; of remaining 56, 15 had insurance coverage that carved out physical therapy from the interdisciplinary program--these patients form the control group
Rome 2004 ^205^ | average 94 mos. pain duration (range 4 mos. to 58 years), half had previously received treatment in a formal pain clinic; all reasonable medical and surgical options for symptomatic relief must have been explored pre-admission | | multiple diagnoses | exclusion: non-pain diagnosis (e.g., chronic fatigue), 18 pts who came directly from addiction rehab (excluded because no pre-opioid withdrawal baseline data were available)
Sanders 1993 ^26^ | average pain duration of 5.25 years, average pain-related surgeries of 0.45, 43% receiving compensation for pain | | varied: 42% low-back pain, 21% cervical back, 8% headache, 23% upper or lower extremity, 6% other pain
Scerri 2006 ^206^ | at least 7 weeks' sick leave at referral or 12 weeks' over the past 2 years; chronic low-back pain | | chronic low back pain | expected benefits from returning to work after program, age 18-61, ability to understand and speak French; exclusion: acute neurological deficit, severe low back pain or sciatica, pregnancy, acute inflammatory rheumatic disease, infectious discitis, spinal fracture within past 3 months, osteoporosis, tumor, severe heart failure or respiratory failure, current involvement in litigation related to low back pain
Scharff 1994 ^25^ | recurrent headaches, mean duration 19.3 years | recurrent headaches, mean duration 15.9 years | recurrent headache, majority Migraine or Rebound | comparison group was 39 pts referred for treatment who declined due to time constraints, commute time, or lack of insurance coverage
Skinner 1990 ^207^ | duration of pain from 1 to 12 years; all patients failed to respond to standard conventional treatments over a number of years and showed no significant change during baseline period of observation | | 48% chronic low back pain (mechanical instability), 15% Cervical Spondylosis | age 18-70, major continuing disability from chronic non-malignant pain despite all appropriate physical investigations and treatments having been tried; without “marked learning difficulties,” without past history of serious mental illness, fluent in English, able to make their own way to the hospital
Skouen 2002 ^208^ | long-term sick-listed employees with MSK pain (on sick leave for at least 8 weeks or not currently on sick-leave, but sick-listed for at least 2 months per year for the last 2 years for MSK pain | same | chronic low-back pain | hold permanent jobs, be sick-listed more than 50% exclusions: active rheumatologic disease, progressive neurologic disease, serious cardiac or other internal medical conditions, decreased lung capacity, malignant basic diseases, acute traumas, infections, acute vascular catastrophes, pregnant, insufficient knowledge of Norwegian language, loss of vision or hearing, registered substance abusers
Skouen 2006 ^29^ | long-term sick-listed employees with MSK pain (on sick leave for at least 8 weeks or not currently on sick-leave, but sick-listed for at least 2 months per year for the last 2 years for MSK pain | same | Chronic Widespread Pain | hold permanent jobs, be sick-listed more than 50% exclusions: active rheumatologic disease, progressive neurologic disease, serious cardiac or other internal medical conditions, decreased lung capacity, malignant basic diseases, acute traumas, infections, acute vascular catastrophes, pregnant, insufficient knowledge of Norwegian language, loss of vision or hearing, registered substance abusers
Snow 1988 ^209^ | | | Chronic Pain syndrome | exclusions: operable medical conditions, psychotic states, malingering
Snow 1990 ^210^ | multi-year history of pain in multiple locations; no relief from chiropractic, outpatient PT | | multiple pain locations including lower back, neck, arms, legs, feet
Spinhoven 2004 ^211^ | mean pain duration of 9.8 years (range 10 mos to 40 years); 79% receiving disability compensation (mean duration 3.7 years); 39% received back surgery, 28% used supportive equipment for ambulation; comorbidities included 40-46% with phobias, 30% with depressive disorder | included in figures for MPP population | low-back pain | inclusion: age 18-65, 6+ mos low-back pain, discrepancy b/w objective findings and pain complaints, cooperation of spouse/relative/close friend to participate in weekly spouse training; exclusion: illiteracy, pregnancy, involvement in litigation concerning social disability income, alcohol or drug abuse, serious psychopathology (e.g., antisocial personality disorder, psychosis, or organic brain damage), specific medical disorders requiring medical treatment or rendering patients unable to participate in program
Stans 1989 ^212^ | mean duration of pain 7.4 years (range 2 to 25 years); 51% vocationally disabled, 14% unemployed | | 54% low-back pain | exclusion: currently awaiting or being considered for a specific medical, technical or surgical intervention; pts with severe psychiatric disturbances; pain related to a malignant process; pain of less than 6 mos duration inclusion: freely accepted philosophy of the program and motivated to take up a more active attitude; continued to suffer despite multiple treatment interventions
Sterner 2001 ^213^ | Duration of pain 3-12 months | N/A | chronic symptoms of Whiplash Associated Disorders (Quebec Task Force WAD 1 to 3) with onset within 3 days of injury | age 18-65; no former neck/shoulder complaints, no indication of brain injury, no severe or systemic debilitating diseases; no indication of drug abuse or abuse of analgesics; no difficulty understanding Swedish
Storro 2004 ^214^ | on sick-leave for pain (average sick-leave = 6 mos.) | on sick-leave for pain (average sick-leave = 6 mos.) | Non-specific neck and shoulder pain, lower back pain, lower back pain with radiating pain
Suman 2009 ^20^ | mean duration of symptoms 9.8 years; 48% currently employed | | Fibromyalgia | no glucocorticoids or immunosuppressive agents for at least 3 months before study; exclusions: symptoms of psychiatric disorders which would prevent compliance with daily requirements of program (e.g., psychosis, OCD, other personality disorders); medical disease which prevented physical exercise, unwilling to stop analgesic medications
Suoyrjo 2008 ^215^ | rate of very long (more than 21 days) sickness spells before rehab: 26.8 per 100 person-years for back-pain rehabilitees, 15.4 for neck-pain rehabilitees | rate of very long (more than 21 days) sickness spells before rehab: 9.5 per 100 person-years | chronic back or neck pain | full-time public sector employees in 10 towns in Finland exclusions: excluded those at work less than three months in the year the rehab started, those not in service four years after rehab, those granted rehab for MSK reasons other than chronic back or neck pain, those at work less than 3 months in a randomly selected year plus or minus three years between 1994 and 2002
Tollison 1985 ^216^ | average 32 months duration (range 5 to 96); average 2.1 major back operations | | low back pain | no significant clinical evidence of surgically or medically remediable pain; cooperation in psychological and physical examination and testing; cooperation and active involvement of spouse and family; staff agreement that pt is motivated to reduce pain and disability; no debilitating psychologic/psychiatric disturbance
Tollison 1989 ^217^ | 6+ months duration (avg. 409 days); 20% had undergone back surgery | acute pain pts were also assessed, but no further info will be abstracted here | low back pain | no significant clinical evidence of surgically or medically remediable pain; cooperation in psychological and physical examination and testing; cooperation and active involvement of spouse and family; staff agreement that pt is motivated to reduce pain and disability; no debilitating psychologic/psychiatric disturbance
Tollison 1990 ^218^ | 22 to 25 months pain duration, average 1.1 to 1.3 major back surgeries | | low back pain | study compared compensated vs. non-compensated pts
Trief 1995 ^219^ | average duration 2 to 4 years (minimum 6 mos.); “have had the full gamut of medical interventions with little or no success and are identified by their referring physicians and the program physician as treatment resistant. As a group, they represent the most intransigent subgroup of chronic back-pain syndrome patients, with 90% unemployed and 95.7% on compensation/disability.” | | chronic low back pain | Exclusions: psychosis, less than 6 mos. pain duration; for this study, pts with no family or who were living alone were excluded
Turk 1998 ^12^ | mean FMS duration of pain was 117 months | | Fibromyalgia | met 1990 American College of Rheumatology classification criteria for FMS
Turner-Stokes 2003 ^76^ | 10.26 years average “chronicity,” 23% on sick leave | 6.76 years average “chronicity,” 23% on sick leave | chronic pain; 95% pain centered on the spine | pain 6+ mos, pt still actively seeking help; age 18+, failed conventional treatment, able to get to clinic without hospital transport, no major changes in medical management anticipated in the next 6 mos, acceptance of the program's philosophy
van Wilgen 2009 ^220^ | chronic pain at least one year plus severe disuse syndrome; mean 8 years pain duration; mean 5 prior medical specialists consulted before MPP; 54% receiving disability pension | Same population | chronic pain, severe disuse syndrome; 38% back and leg pain, 20% neck/shoulder/arm, 19% total body or body side; 15% back pain and/or neck pain | inclusion: chronic pain longer than 1 year, not suitable for treatment in primary care, severe disuse syndrome, full agreement of the patient and the team, informed consent; exclusion: ongoing medical treatment, nociceptive pain, persistent cognition of a somatic cause for pain, requests/demands for additional advanced medical diagnostics
Vendrig 1999 ^221^ | mean pain duration 46.3 months; mean disability time 13.8 months; 22% had prior spinal surgeries | | chronic back pain | pain duration at least 3 mos; no structural pathology of spine
Vendrig 2000 ^222^ | duration: at least 3 months (mean 47.6 mos.); | N/A | no structural pathology of spine (moderate degenerative changes of the intervertebral disc not considered structural pathology) | 2 pts excluded due to invalid MMPI-2 scores (VRIN scale scores over 80)
Vendrig 2000 ^223^ | mean duration of symptoms 20.8 mos; mean duration of absenteeism due to symptoms was 15.7 mos. | | chronic symptoms from whiplash injury | 6+ mos since injury; partially or completely unable to work due to symptoms; no symptoms or signs of an objective neurologic deficit detected at physical exam or with imaging
Verra 2009 ^22^ | 12% employed full time, 43% employed part time; 27% pain duration less than 5 years, 4% pain duration less than 1 year | | fibromyalgia | failed outpatient treatment, FM of at least 6 months duration; willingness to learn behavioral patterns and motivation to participate in graded activity exercise programs; ability to formulate realistic functional goals, sufficient cognitive abilities and German language skills to understand the content of the interventions, agreement/informed consent exclusion: severe somatic illness requiring specific treatment (e.g., cancer, inflammatory rheumatic disease, neurologic disease, post-surgery pain); manifest psychiatric disorder such as dementia, psychosis, suicidality
Vines 1996 ^224^ | average pain duration of 9+ years (range 2 months to 32 years); no further useful medical or surgical interventions; experiencing significant difficulty in other areas of life, such as daily activity, emotional, vocational, or social functioning | | multiple; 57% spine-related | excluded for medical or psychiatric problems not under control; “if substance abuse is an issue, pain rehabilitation is delayed until the substance abuse has been treated
Vines 2000 ^225^ | average pain duration of 93 months (range 8 to 420); no further useful medical or surgical interventions | | back pain | able to read/write English; no current cancer, HIV/AIDS, pregnancy, or recent birth; not currently abusing alcohol; no history of psychiatric disease; aged 18-65
Vollenbroek-Hutten 2004 ^226^ | median pain duration 72 months; mean visits to a PT in 6 mos. before program = 15 | median pain duration 48 months; mean visits to a PT in 6 mos. before program = 11 | chronic aspecific low back pain | pain duration longer than 3 months, age 18-60, no back surgery in past 3 months; exclusion: structural pathology, medical contraindication for physical training
Vowles 2004 ^227^ | mean pain duration of 21.5 months (range 3 to 115); none of the patients had successfully returned to work since injury; all pts had sustained work-related injuries and were unemployed and receiving Workman's Comp at onset of treatment; 53% had a job available with prior employer following treatment | | 68% low back pain | for admission, must have 90+ days pain, no psychotic symptoms, explicit goal of improving functioning and/or returning to work; exclusion: requiring surgical intervention
Vowles 2007 ^228^ | mean pain duration of 96 mos (range 15 to 720 mos) | | 40% low back pain, 16% full body, 12% lower limb, 11% upper limb, 11% neck; 76% multiple sites | not described
Vowles 2008 ^229^ | 76.3% unemployed, 76.6% receiving disability or wage replacement allowance; median pain duration was 96 mos (range 8 to 516 mos); 52% of patients had a general, nonspecific diagnosis (e.g., chronic pain syndrome, musculoskeletal pain, postsurgical pain), 36% diagnosed with FM | | 46% low back pain, 18% shoulder/arms, 12% legs/pelvic, 3% neck; 57% multiple pain sites | significant levels of pain-related distress and disability, agreement with the rehabilitative (as opposed to curative) goals of treatment; no further medical tests of procedures required; no conditions that could interfere with participation in a group-based treatment program (i.e., impaired neuropsychological functioning, poorly controlled psychiatric conditions)
Vowles 2010 ^230^ | 73% unemployed, 73% receiving disability or wage replacement allowance; median pain duration was 96 mos (range 8 to 360 mos) | | 44% low back pain, 21% upper extremity, 11% lower extremity, 3% neck; 55% multiple pain sites | not reported
Walsh 2002 ^231^ | referred from Pain Clinic and Orthopaedic Departments at King's Mill Centre Hospital (48% from each department); “very severe disability” at referral time | | chronic low-back pain | lower-back pain for 12+ mos; disability primarily caused by low-back pain as perceived by pt and assessor; pt positively opted in. Exclusion: conditions requiring individual medical, surgical, or psychological treatment; pending investigations or treatment for low back pain; pt not willing to participate; major disability due to factors other than low back pain; age <18 years; participation in a related low back pain program during preceding 6 mos
Walsh 2004 ^232^ | 12+ months pain in lower back | | low-back pain | Study inclusion: Completed treatment; exclusion criteria: conditions requiring “individual medical, surgical or psychological treatment, pending investigations or treatment for low back pain, pt not willing to participate in program, major disability caused by factors other than low-back pain, age younger than 18 years, participation in a related low-back pain program within preceding 6 months”
Wang 2008 ^47^ | all pts had disabling pain of at least 3 months duration that led to sick leave of at least 6 weeks; mean duration of pain 20 months | | chronic low back pain | chronic low-back pain as major symptom, age between 18 and 65, adequate command of “domestic language,” specific etiologies of the neck or lower back pain were excluded (e.g., tumor, trauma, inflammatory disease or infection, radicular sensorimotor deficits in upper or lower extremity, severe degenerative changes, structural pathology of the lumbar spine), rheumatological disease, serious cardiopulmonary, vascular, or other internal medical conditions, any sensorimotor and/or neurological deficits in the lower extremity, spinal surgery in the year before admission to treatment, any other major pain location; for this study, patients with medications that potentially influence levels of inflammatory parameters were excluded (NSAIDS, aspirin, corticosteroids) within the 4 weeks prior to the study
Wasan 2004 ^233^ | chronic pain for at least 2 years; multiple medication trials and/or procedural treatments for chronic pain; psychiatric comorbidities: Major Depression (MDD) and Pain associated with psychological factors and a general medical condition (PAPFGMC) | | most frequent pain diagnosis: low back (just under half)
Williams 1993 ^234^ | mean duration of pain 10.5 years (range 1 to 47 years; 48% had received at least one operation for pain; 15% were employed full or part time; 13% had unresolved compensation claims | | chronic pain: 68% spinal pain; 16% torso pain | Included with at least two of the following: widespread disruption in activity (except work) owing to pain; habitual overactivity leading to increased pain; use of excessive medication related to pain problems (regular use of analgesics and/or sedatives for more than 6 mos w/o adequate relief); high affective distress score on assessment or clear signs or reports of emotional distress attributed by the patient to pain; use of unnecessary aids, such as crutches or a corset, assessed during medical examination by the anaesthetist; high levels of reported or observed pain behaviour; work reduced, impaired or ceased owing to pain. Patients were excluded if they fulfilled one of the following criteria: cannot use English, written or spoken; cannot climb stairs; current psychotic illness; unavailable for a four week period; suitable for further physical treatment, assessed during medical examination; pain for less than one year; less than 18 years old; currently using opiod analgesics prescribed as treatment for drug dependence, or not prescribed for patient.
Williams 1999 ^49^ | Referred from pain clinics and orthopedic services when all attempts to resolve the pain problem were exhausted without significant benefits, and multicomponent rehabilitation was not available locally. Randomized pts: mean pain duration of 108 mos; 73% had been hospitalized for pain; 49% had 1+ surgeries for pain; 12% employed and working; 63% on disability welfare Elective inpatients: mean pain duration of 126 mos; 79% had been hospitalized for pain; 49% had 1+ surgeries for pain; 22% employed and working; 59% on disability welfare Elective outpatients: mean pain duration of 127 mos; 59% had been hospitalized for pain; 36% had 1+ surgeries for pain; 37% employed and working; 53% on disability welfare | waitlist control population information included with “randomized pts” | Chronic pain: 79% to 86% had MSK pain, 35% to 46% of pts attributed their pain to an accident | Patients were required to meet two of the following criteria for eligibility for treatment: work impaired by pain; non-work activity impaired by pain; habitual overactivity/underactivity cycles; significant distress attributable to pain; overuse of analgesic or psychotropic drugs for pain; overuse of aids; and high levels of reported or observed pain behavior. Patients were excluded if they were suitable for further medical or physical treatment for pain; were currently psychotic or suicidal; unable to read or write English; if they had pain for less than one year; were under 18 years old; currently using opioids illegally; or unable to climb one flight of stairs (necessitated by the treatment site).
Wong 2009 ^235^ | average pain duration 9.9 years, range 1-38 years; completed all medical investigations and planned treatments for pain | | non-progressive, non-inflammatory chronic conditions | social, physical, and psychological functioning significantly affected by chronicity of pain; all medical and surgical treatments and investigations completed before referral with little to no benefit gained from those treatments; only non-progressive, noninflammatory chronic MSK conditions (FM, back and neck pain, osteoarthritis, etc.) included; pts with major psychiatric disorders that would interfere with group participation are excluded (schizophrenia, compulsive-obsessive disorders, major anxiety and depressive disorders); “as part of self-management, they must be able to find their own transport to the PMP,” able to communicate “reasonably well” in English; able to look after their own personal hygiene; committed to learning self-management skills and strategies, able to attend introductory session and at least 6 of the 8 sessions
Wormgoor 2008 ^236^ | median pain duration of 24 to 60 months (depending on diagnosis group); median current sick listing of 77.5 to 80 days | | chronic specific back pain (caused by a specific pathophysiological mechanism), chronic non-specific back pain, chronic widespread pain | exclusions: no-longer sick-listed, had a sickness grade of less than 75%, received a disability pension, were pregnant, were on sick leave due to back-surgery, were taking medication influencing heart rate response, or were employed as civil servant; pts with serious functional disability (somatic or psychological) were referred to a different program
Wright 1999 ^237^ | 4+ mos. post-injury; surgical treatment (or further surgical treatment) ruled-out; average 16 to 20 months post-injury | | chronically disabled patients with work-related spine disorders of cervical or lumbar spine | compensation injury (i.e., work-related); no extremity-only injuries
Zunin 2009 ^238^ | duration at least 1 year; referred for screening for following reasons: “pain that is disproportionate to that of the diagnosis, recovery time exceeding expected resolution, sustained or increased use of triptans and/or opiate analgesics, prolonged or frequently recurring absenteeism, noncompliance with previous medical treatment plans, history of frequent changes in physician, history of multiple concurrent physicians, high emergency department utilization, and/or a history of poorly coordinated care” | N/A | multiple diagnoses | study includes only program completers

Table D-2 Treatment components

Citation | MPP: Medical Component and Definition | MPP Behavioral Component and Definition | MPP Physical Recondition Component and Definition | MPP Education Component and Definition | Other MPP Components | MPP Length/Frequency | Comparison Treatment Description
Alaranta 1994 ^91^ | baseline medical exam by physiatrist, team carrying out program included physician | cognitive-behavioral disability management groups (relaxation, visual images, etc.) | cardiovascular endurance exercises, muscular strength and endurance exercises, stretching; no passive PT | 5 hours of discussion groups per week including improving skills to cope with pain, problem solving, etc. | included group therapy (no info on group size) | 3 weeks home-based exercise post-baseline exam; 3 weeks inpatient, 42+ hours per week | 3 week inpatient “current national type” treatment; passive physical therapy (massage, electrical therapies, traction, etc.), muscle training, pool exercises, back school education. Less strenuous than AKSELI (15-20 hr/wk physical activity vs. 37 hr/wk for AKSELI); no stress management group provided
Altmaier 1992 ^92^ | inpatient program at a hospital; medications monitored to allow only aspirin and Tylenol | operant conditioning on exercise behaviors, relaxation training, biofeedback training, cognitive-behavioral coping skills, daily homework exercises | twice-daily PT and daily aerobic fitness | daily education on mechanisms of pain; vocational rehab | | 3 weeks inpatient | same as MPP EXCEPT behavioral component (not provided)
Andary 1997 ^93^ | program direct by a physiatrist | psychological services facilitated the development of coping strategies and goal achievement | PT focused on maximizing physical function through building strength, endurance, and flexibility | Chronic pain education sessions dealt with understanding chronic pain physiology and life skills development | nutrition, vocational services | 9 hours per week; treatment plans reviewed bimonthly; completion contingent on achievement of vocational/avocational goals (mean 459 days for TBI pts, 295 days for non-TBI)
Angst 2006 ^18^ | regular medical consultations (1 hour/week) including drug therapy | individual psychotherapy including cognitive behavioral therapy; participation in a behavioral therapeutically oriented pain coping/management group, creative activities, relaxation therapy | 5-6 daily sessions of individual, active PT (average 5 hours per week); aerobic endurance training | 3 hours per week of education about pathophysiology and management of chronic disabling pain | traditional Chinese medicine, mainly Qigong (3 hours per week) | 4-weeks
Angst 2009 ^21^ | regular medical consultations (1 hour/week) including drug therapy | individual psychotherapy including cognitive behavioral therapy; participation in a behavioral therapeutically oriented pain coping/management group, creative activities, relaxation therapy | 5-6 daily sessions of individual, active PT (average 5 hours per week); aerobic endurance training; movement analysis (Cary Rick method) | 3 hours per week of education about pathophysiology and management of chronic disabling pain | traditional Chinese medicine, mainly Qigong (3 hours per week) | 4-weeks | Standard inpatient rehab at the same clinic: very similar to MPP, except less behavioral content (only relaxation therapy and optional individual CBT); length is 3 weeks rather than four; much less interdisciplinary communication (30 minutes for 20 patients vs. 2 hours for 6 patients in the MPP)
Bailey 2003 ^94^ | nursing assessment daily, physician rounds weekly | group psychotherapy daily; some also received individual psychotherapy, biofeedback, hypnotherapy, marital/family therapy | daily PT, daily OT | 2 daily psychoeducational group sessions | acupuncture | 8 hrs per day/5 days per week; for 4-8 weeks (mean 5.9 weeks)
Bendix 1998 ^95^ | initial exam by a physician; education included spinal anatomy and pathology, sexuality pain, nutrition, and medication | daily group therapy and relaxation, average of one individual counseling session per week; pts urged to “take greater responsibility for coping with pain, set realistic personal goals, change the negative sensation of pain into a more positive way of living, and give themselves credit for their achievements” | daily aerobics, weight training, work simulation, work hardening, stretching, active recreation | daily theoretical class (see “medical” for content) | carried out in groups of seven with pts in varying stages within the same group (i.e., “third-weekers” “inspire the ‘first-weekers’ to endure and encourage them to continue. This also gives the ‘third-weekers’ a responsibility and authority in relation to the beginners, which in turn increases self-confidence” | 3 weeks, 39 hours per week, intensive portion followed by 6 hours once per week for 3 weeks | one control group of no treatment, 2 control groups in less intensive programs totaling 24 hours of treatment time: active physical training and traditional back school OR active combined psycho-physical program
Bendix 1995 ^81^ | initial exam by a physician; education included spinal anatomy and pathology, sexuality pain, nutrition, and medication | daily group therapy and relaxation, average of one individual counseling session per week; pts urged to “take greater responsibility for coping with pain, set realistic personal goals, change the negative sensation of pain into a more positive way of living, and give themselves credit for their achievements” | daily aerobics, weight training, work simulation, work hardening, stretching, active recreation | daily theoretical class (see “medical” for content) | carried out in groups of seven with pts in varying stages within the same group (i.e., “third-weekers” “inspire the ‘first-weekers’ to endure and encourage them to continue. This also gives the ‘third-weekers’ a responsibility and authority in relation to the beginners, which in turn increases self-confidence” | 3 weeks, 39 hours per week, intensive portion followed by 6 hours once per week for 3 weeks | 2 less intensive programs totaling 24 hours of treatment time: active physical training and traditional back school OR active combined psychophysical program
Bendix 1996 ^43^ | initial exam by a physician; education included spinal anatomy and pathology, sexuality pain, nutrition, and medication | daily group therapy and relaxation, average of one individual counseling session per week; pts urged to “take greater responsibility for coping with pain, set realistic personal goals, change the negative sensation of pain into a more positive way of living, and give themselves credit for their achievements” | daily aerobics, weight training, work simulation, work hardening, stretching, active recreation | daily theoretical class (see “medical” for content) | carried out in groups of seven with pts in varying stages within the same group (i.e., “third-weekers” “inspire the ‘first-weekers’ to endure and encourage them to continue. This also gives the ‘third-weekers’ a responsibility and authority in relation to the beginners, which in turn increases self-confidence” | 3 weeks, 39 hours per week, intensive portion followed by 6 hours once per week for 3 weeks | no treatment from center: could go anywhere else for treatment
Bendix 1997 ^79^ | initial exam by a physician; education included spinal anatomy and pathology, sexuality pain, nutrition, and medication | daily group therapy and relaxation, average of one individual counseling session per week; pts urged to “take greater responsibility for coping with pain, set realistic personal goals, change the negative sensation of pain into a more positive way of living, and give themselves credit for their achievements” | daily aerobics, weight training, work simulation, work hardening, stretching, active recreation | daily theoretical class (see “medical” for content) | carried out in groups of seven with pts in varying stages within the same group (i.e., “third-weekers” “inspire the ‘first-weekers’ to endure and encourage them to continue. This also gives the ‘third-weekers’ a responsibility and authority in relation to the beginners, which in turn increases self-confidence” | 3 weeks, 39 hours per week, intensive portion followed by 6 hours once per week for 3 weeks | 2 less intensive programs totaling 24 hours of treatment time: active physical training and traditional back school OR active combined psychophysical program
Bendix 1998 ^96^ | initial exam by a physician; education included spinal anatomy and pathology, sexuality pain, nutrition, and medication | daily group therapy and relaxation, average of one individual counseling session per week; pts urged to “take greater responsibility for coping with pain, set realistic personal goals, change the negative sensation of pain into a more positive way of living, and give themselves credit for their achievements” | daily aerobics, weight training, work simulation, work hardening, stretching, active recreation | daily theoretical class (see “medical” for content) | carried out in groups of seven with pts in varying stages within the same group (i.e., “third-weekers” “inspire the ‘first-weekers’ to endure and encourage them to continue. This also gives the ‘third-weekers’ a responsibility and authority in relation to the beginners, which in turn increases self-confidence” | 3 weeks, 39 hours per week, intensive portion followed by 6 hours once per week for 3 weeks | one control group of no treatment, 3 control groups of less intensive programs: 2 totaling 24 hours of treatment time: active physical training and traditional back school OR active combined psycho-physical program; 1 totaling 48 hours total treatment time of pure physical training, offered 2 hours, 3 times per week, for 8 weeks
Bendix 1998 ^97^ | initial exam by a physician; education included spinal anatomy and pathology, sexuality pain, nutrition, and medication | daily group therapy and relaxation, average of one individual counseling session per week; pts urged to “take greater responsibility for coping with pain, set realistic personal goals, change the negative sensation of pain into a more positive way of living, and give themselves credit for their achievements” | daily aerobics, weight training, work simulation, work hardening, stretching, active recreation | daily theoretical class (see “medical” for content) | carried out in groups of seven with pts in varying stages within the same group (i.e., “third-weekers” “inspire the ‘first-weekers’ to endure and encourage them to continue. This also gives the ‘third-weekers’ a responsibility and authority in relation to the beginners, which in turn increases self-confidence” | 3 weeks, 39 hours per week, intensive portion followed by 6 hours once per week for 3 weeks | one control group of no treatment, 2 control groups in less intensive programs totaling 24 hours of treatment time: active physical training and traditional back school OR active combined psycho-physical program
Bendix 2000 ^78^ | initial exam by a physician; education included spinal anatomy and pathology, sexuality pain, nutrition, and medication | daily group therapy and relaxation, average of one individual counseling session per week; pts urged to “take greater responsibility for coping with pain, set realistic personal goals, change the negative sensation of pain into a more positive way of living, and give themselves credit for their achievements” | daily aerobics, weight training, work simulation, work hardening, stretching, active recreation | daily theoretical class (see “medical” for content) | carried out in groups of seven with pts in varying stages within the same group (i.e., “third-weekers” “inspire the ‘first-weekers’ to endure and encourage them to continue. This also gives the ‘third-weekers’ a responsibility and authority in relation to the beginners, which in turn increases self-confidence” | 3 weeks, 39 hours per week, intensive portion followed by 6 hours once per week for 3 weeks | 36 hours total treatment time of pure physical training, offered at a frequency of 1.5 hours, 3 times per week, for 8 weeks
Bliokas 2007 ^98^ | presenters included medical and dietetics disciplines (among others); education items included medication issues | presenters included psychology discipline (among others); education items included stress management, problem-solving, cognitive restructuring, changing maladaptive behaviors, effective communication, goal-setting and monitoring and achieving goals; 45-minute relaxation training session every day of attendance | graded activity including 1-hour exercise session of walking and stretching, supervised by PT; OT, PT, and exercise science presentations | psychoeducational group therapy (see other components for content) | approximately half the MPP group got an additional “Graded Exposure” component which included individual meetings with a psychologist to identify their most-feared “avoided activities” which were then approached using cognitive-behavioral graded exposure techniques | 8 weeks, 2 days per week (total 66.5 hours) | wait-list for treatment program
Buchner 2006 ^99^ | initial evaluation including clinical exam, radiographic exam, and MRI of the cervical or lumbar spine | improve skills for individual coping and emotional control; psychotherapy, behavioural therapy, both individual and group sessions | physical exercises, ergonomic training, education in back-protection techniques and protective behaviour; goal to increase the pts' activity levels at home and day-to-day functioning to facilitate a return to the workplace | included with physical and behavioral | | 3 weeks, 8-hrs per day, 5 days per week
Buchner 2007 ^100^ | initial evaluation including clinical exam, radiographic exam, and MRI of the cervical or lumbar spine; some education sessions delivered by orthopedic surgeon; daily sessions with physician | improve skills for individual coping and emotional control; psychotherapy, behavioural therapy, both individual and group sessions; daily sessions with psychologist | physical exercises, ergonomic training, education in back-protection techniques and protective behaviour; goal to increase the pts' activity levels at home and day-to-day functioning to facilitate a return to the workplace | included with physical and behavioral | | 3 weeks, 8-hrs per day, 5 days per week
Buchner 2007 ^101^ | initial evaluation including clinical exam, radiographic exam, and MRI of the cervical or lumbar spine; some education sessions delivered by orthopedic surgeon; daily sessions with physician | improve skills for individual coping and emotional control; psychotherapy, behavioural therapy, both individual and group sessions; daily sessions with psychologist | physical exercises, ergonomic training, education in back-protection techniques and protective behaviour; goal to increase the pts' activity levels at home and day-to-day functioning to facilitate a return to the workplace | included with physical and behavioral | | 3 weeks, 8-hrs per day, 5 days per week
Burnham 2010 ^23^ | initial 2-hr medical care assessment, group discussion facilitated by psychologist or nurse; physician lectures included on pain pathophysiology and medications | group therapy facilitated by psychologist; 1-hr group education and psychotherapy session; psychologist lectures on sleep hygiene, coping strategies, stress and mood management | exercise specialist and physical therapist offered education on adverse effects of deconditioning and the dynamics of pain and maintaining a health spine | included with others | | once per week for 5 hrs each time; duration 2-3 months depending on individual progress; pts discharged when goals met, progress plateaued, or pt was non-compliant | group of 4-6 pts, used book Managing Pain Before it Manages You by M Caudill as basis of weekly group discussion
Burns 2000 ^102^ | “treatment by a physician” | individual (2 hrs per week) and group (2 hrs per week) CBT, biofeedback | 5 hrs per day PT and OT aimed at increasing physical capacity through weight training, treadmill use, stretching, walking outdoors | “education about pain” | | 4 weeks, 5 days per week
Burns 1998 ^103^ | “treatment by a physician” | individual (2 hrs per week) and group (2 hrs per week) CBT, biofeedback | 5 hrs per day PT and OT aimed at increasing physical capacity through weight training, treadmill use, stretching, walking outdoors | “education about pain” | | 4 weeks, 5 days per week
Burns 1998 ^104^ | “treatment by a physician” | individual (2 hrs per week) and group (2 hrs per week) CBT, biofeedback | 5 hrs per day PT and OT aimed at increasing physical capacity through weight training, treadmill use, stretching, walking outdoors | “education about pain” | | 4 weeks, 5 days per week
Burns 2003 ^105^ | medication management by a physician | individual and group CBT, approx 2 hours per week geared toward decreasing maladaptive thoughts and appraisals of pain and disability, teaching adaptive coping skills | PT and OT approximately 5 hours per day | “education about pain” | | 4 weeks, 5 days/week
Burns 2003 ^106^ | medication management by a physician | individual and group CBT, approx 2 hours per week geared toward decreasing maladaptive thoughts and appraisals of pain and disability, teaching adaptive coping skills | PT and OT approximately 5 hours per day | “education about pain” | | 4 weeks, 5 days/week
Burns 2005 ^107^ | medication management by a physician | individual and group CBT, approx 2 hours per week geared toward decreasing maladaptive thoughts and appraisals of pain and disability, teaching adaptive coping skills | PT and OT approximately 5 hours per day | “education about pain” | | 4 weeks, 5 days/week
Carleton 2010 ^108^ | initial clinical exam; treatment team included pt's family physician, education on pain, process of tissue healing, and how fitness and nutrition impact healing | 1 hr per week of psychological counseling; 1 hr of relaxation-based pain management | graded activity, general conditioning, work-hardening; team included PT, OT, kinesiologist | included with medical and behavioral | | 6-weeks
Cassisi 1989 ^109^ | program run by Neurosurgical Surgery department, “intense, highly integrated, aggressive program of physical medicine …”; “detoxification is ordered for every patient” | psychologically based therapies including biofeedback and stress management | PT, ergonomics, and vocational rehab; job simulation and work conditioning | education for coping techniques | | 4 weeks, 6 days per week, 10 hours per day; generally half inpatient, half outpatient | varied, through other providers
Cedraschi 2004 ^16^ | education discussions included a rheumatologist, clinical exam by physician | relaxation exercises, education-discussions led by psychologist addressing personal relationships | swimming pool sessions and low-impact land-based exercises led by a PT; OT led sessions on ADLs | education-discussions on scientific knowledge about FM, associated conditions, symptoms, modulating factors, and personal relationships | | 12 sessions, 2 times per week for 6 weeks | wait list for treatment
Chapman 1990 ^110^ | withdrawal from narcotics, barbiturates, and tranquilizers; series of 6-10 lumbar sympathetic nerve blocks | group therapy, group relaxation training, individual psychological assessment and therapy if indicated | PT exercises | teach improved self-management of pain and related symptoms | pts with pending disability claims received vocational evaluation and counseling | inpatient and outpatient treatment included approx same number of treatments, but inpatients completed in 2-3 weeks, outpatient in 6-10 weeks; determination of in- vs. outpatient based on financial coverage, need for drug withdrawal in a supervised setting, and assessment from initial med exam that pt would need “careful monitoring of behavior during treatment”
Chapman 1994 ^111^ | withdrawal from narcotics, barbiturates, sedatives, and tranquilizers; series of 6-10 lumbar sympathetic nerve blocks | group therapy, group relaxation training, individual behavioural therapy to discuss problems of coping and set specific goals for activity increase | individual PT sessions to teach improved body mechanics and increase strength and ROM, with prescription of home exercises; OT to teach adaptive activity patterns | group education with pts and families regarding nature and management of chronic pain and related problems | vocational evaluation and counseling when appropriate | inpatient (27%) and outpatient (73%) treatment included approx same number of treatments, but inpatients completed in 2-3 weeks, outpatient in 6-10 weeks; determination of in- vs. outpatient based on need for drug withdrawal in a supervised setting, or if no one would be available to monitor pt at home after nerve blocks
Chapman 1996 ^112^ | Center A: withdrawal or reduction from narcotics, barbiturates, and tranquilizers; series of lumbar sympathetic nerve blocks or trigger point injections if pt was assessed as having sympathetically maintained pain or pain related to the presence of trigger points; pts saw physician each time he/she visited the clinic Center B: Medical assessment; reduction/elimination of opioids, tranquilizers, barbiturates; epidural steroid and trigger point injections or sympathetic nerve blocks offered as medically indicated | Center A: group therapy to discuss pain and stress management issues and to reinforce functional improvement; group and individual relaxation training Center B: Group and individual therapy, biofeedback when indicated, group sessions with families to address family issues related to chronic pain and its management | Center A: group and individual PT sessions to teach improved body mechanics and increase strength and ROM, with prescription of home exercises Center B: daily group aerobics and individual exercises to increase physical function and stamina | Center A: Psychologist and Physician alternated presenting educational lectures about different aspects of pain and its management Center B: Psychologist-led educational groups | | Center A: 6-10 visits of 4-5 hours each Center B: 3 days/week for 5 weeks
Chapman 2000 ^50^ | Center A: withdrawal or reduction from narcotics, barbiturates, and tranquilizers; series of lumbar sympathetic nerve blocks or trigger point injections if pt was assessed as having sympathetically maintained pain or pain related to the presence of trigger points; pts saw physician each time he/she visited the clinic Center B: Medical assessment; reduction/elimination of opioids, tranquilizers, barbiturates; epidural steroid and trigger point injections or sympathetic nerve blocks offered as medically indicated Center C: Led by physicians trained in Anesthesiology, Physiatry, and or psychiatry; physicians saw pts for 1.5 hours each week for education centering around the nature of chronic pain and the medical rationale for rehab approaches | Center A: group therapy to discuss pain and stress management issues and to reinforce functional improvement; group and individual relaxation training Center B: Group and individual therapy, biofeedback when indicated, group sessions with families to address family issues related to chronic pain and its management Center C: daily 90-minute psychology group session plus 90-minutes weekly of individual therapy including relaxation methods and biofeedback | Center A: group and individual PT sessions to teach improved body mechanics and increase strength and ROM, with prescription of home exercises Center B: daily group aerobics and individual exercises to increase physical function and stamina Center C: weekly 60-minute swimming, 30 minutes aerobics 4 times a week, 2-hour community outing incorporating walking, 9.5 hours each week of supervised stretching and strengthening and use of treadmill | Center A: Psychologist and Physician alternated presenting educational lectures about different aspects of pain and its management Center B: Psychologist-led educational groups Center C: Physicianled education as noted under medical; also group education with weekly 1-hr sessions on pacing, medication and compliance, and body mechanics and posture | | Center A: 6-10 visits of 4-5 hours each Center B: 3 days/week for 5 weeks Center C: inpatient, generally for 3 weeks (but home on the weekend), 7 hours of treatment per day
Ciechanowski 2003 ^113^ | initial clinical exam; opioid and sedative-hypnotic tapering as needed | individual cognitive-behavioral psychotherapy; group coping skills training | quota-based physical and occupational therapy | group pain education | | 3 weeks, 5.5 days per week (some pts--20% of this cohort--stay longer if they “require additional time to reach maximum gains and have funding for additional time; most of these complete 4 weeks rather than 3)
Connally 1991 ^114^ | pain med withdrawal and medication management; 6-8 lumbar blocks | individual and group psychotherapy, vocational evaluation and counseling | activity reinforcement and stabilization | “patient education” | | average of 13 treatment days (range 10 to 16) occurring over 3 to 10 weeks; 5 inpatient, 12 outpatient
Cott 1990 ^115^ | initial medical assessment | initial behavioral assessment, behavioral psychologist integrated all therapeutics | prescriptions for exercise | education on difference between “hurt” and “harm”; medical vs. non-medical components of illness behavior | some patients also had access to Field Consultants—visited home and workplace, integrated with physical assessments, observation of home environment, etc. | not reported
Crisostomo 2008 ^116^ | Discontinuation or reduction in benzodiazepines and analgesics initiated and coordinated by a physician after admission (unless meds were being used to treat comorbid medical or psych illnesses) | cognitive-behavioral model served as basis for treatment, including biofeedback, relaxation training, stress management, and elimination of pain behaviors | daily PT and OT | Chemical health education, daily cognitive-behavioral group educational sessions | | 3 weeks, 8 hrs per day, 5 days per week
Currie 2003 ^15^ | group co-led by a family physician experienced in chronic pain and addiction medicine; education modules included effects of pain medications, nutrition, etc | basic approach was cognitive-behavioral; included relaxation training, sleep enhancement, substance abuse education | group co-led by an OT experienced in chronic pain and addiction medicine; included pacing skills, stretching and body mechanics | included with other components | groups of 5-9 pts | 10-weeks, weekly meetings
Davis 1992 ^117^ | comprehensive assessment by physician (plus PT and psychologist) to determine suitability | relaxation training, group and individual therapy | daily aerobic training and ROM exercises, resistance training every-other day | “educational classes” and family education | | not described
Deardorff 1991 ^73^ | medication management (goal is reduction and elimination of narcotics and other addictive medications); medical consultation and managed performed under direction of clinic Medical Director | individual pain management, group pain management and education, biofeedback, family counseling and relaxation training | PT emphasizing stretching, strengthening, and conditioning based on behavioral quota system; OT emphasizing body mechanics training, increased sitting and standing, strengthening, work-simulation, and retraining in ADLs | included with behavioral | | mean inpatient days is 20.32, mean subsequent outpatient days is 13.2; of 17 pts receiving only outpatient, mean treatment days was 28.3 | no treatment
Demoulin 2010 ^118^ | team included a physical medicine and rehabilitation specialist; theoretic information on spinal functional anatomy and pathophysiology | team included a psychologist who educated on emotions associated with pain, coping strategies, and impact of chronic pain on quality of life | 25 sessions of physical reconditioning including group sessions and individually tailored exercises; cycle ergometer, muscle toning, stretching, strengthening trunk muscles; weekly individual rehab sessions; team included several PTs and an OT who taught minimization of work-related risks and ergonomics | Back school; components described in med, behav, and phys | offered in groups of up to 8 pts | 36 two-hour sessions at pace of 2 to 3 sessions per week | 4-week waiting list
Dersh 2008 ^119^ | medically directed treatment program | individual counseling and group therapeutics | quantitively directed exercise progression supervised by PT and OT | education focused on disability management, vocational reintegration, stress management, improvement in coping skills, future fitness maintenance | detoxification from all opioid medications early in treatment | not described
Doleys 1986 ^120^ | narcotics users gradually withdrawn from narcotics during first two weeks; all pts underwent 3-day inpatient evaluation prior to acceptance | group and individual therapy, relaxation/biofeed back | PT, OT | family education | detox from narcotics | 4 weeks
Dunstan 2007 ^121^ | education on neurophysiological mechanisms of pain perception; referring GPs served as medical case managers | groups coordinated by clinical psychologist; stress management training, cognitive techniques, social skills training (anger management, appropriate assertiveness, communication, conflict resolution, etc.) | daily walking plus exercises and stretches increasing according to time and/or quota-based schedule; use of graded everyday tasks to build functional tolerances; pacing | education on biopsychosocial model of pain disability, acute vs. chronic pain, links between thoughts, feelings, behaviour, and pain; physiological and psychological benefits of exercise; safe postures and body mechanics | groups; considered “a light multidisciplinary WRAP” (Work Related Activity Program) | 6 weeks; one half-day per week
Dysvik 2004 ^122^ | pre-treatment clinical exam, treatment team included a physician and two nurses, education included understanding causes of pain, what makes pain worse | psychologist on treatment team, education included relaxation, coping strategies, self-esteem, thoughts/feelings/behavior, communication skills | treatment team included physical therapist and ergotherapist; treatment included physiotherapy | see other components for education topics | | 8 weeks, 1 meeting per week, 3 hrs each session; plus two follow-up sessions at 6-mos and 12-mos post-treatment
Dysvik 2005 ^123^ | pre-treatment clinical exam, treatment team included a physician and two nurses, education included understanding causes of pain, what makes pain worse | psychologist on treatment team, education included relaxation, coping strategies, self-esteem, thoughts/feelings/behavior, communication skills | treatment team included physical therapist and ergotherapist; treatment included physiotherapy | see other components for education topics | | 8 weeks, 1 meeting per week, 3 hrs each session; plus two follow-up sessions at 6-mos and 12-mos post-treatment
Edwards 2003 ^124^ | medication management by a physician | cognitive-behaviorally oriented group therapy sessions | daily PT and graded exercise training | didactic sessions on the psychological and behavioral aspects of chronic pain | treated in groups of 4-8 pts | 4 weeks
Elkayam 1996 ^125^ | examination by pain specialist for possible epidural injects; neurologic exam | behavioral pain management training, cognitive behavioral skill training including stress management, individual and group counseling emphasize a crisis intervention mode, family counseling; Alexander technique training | Alexander technique training, back school | Back school | chiropractic spinal manipulation, acupuncture | 4 weeks
Elkayam 1996 ^126^ | examination by pain specialist for possible epidural injects; neurologic exam | behavioral pain management training, cognitive behavioral skill training including stress management, individual and group counseling emphasize a crisis intervention mode, family counseling; Alexander technique training | Alexander technique training, back school | Back school | chiropractic spinal manipulation, acupuncture | 4 weeks
Ersek 2008 ^127^ | groups facilitated by 1 of 2 nurses and 1 psychologist; content included education on pain medication, mechanisms of pain, signs/symptoms that require medical attention | content included challenging negative thoughts, relaxation and breathing techniques, problem solving | strength and balance exercises, activity pacing and rationale for avoiding guarding and inactivity, heat/cold packs | entire program was educational group therapy | | 7 weekly sessions; 90 minutes each | book about chronic pain: either The Chronic Pain Workbook or Managing Your Pain Before It Manages You (book given out switched partway through the study to ensure participants “received current information about pain management”
Evans 2001 ^128^ | medically directed treatment program | individual counseling and group therapeutics | quantitively directed exercise progression supervised by PT and OT | education focused on disability management, vocational reintegration, stress management, improvement in coping skills, future fitness maintenance | | not described
Feuerstein 1993 ^129^ | Initial evaluation including medical exam by physician board certified in physical and occupational medicine | work-related pain and stress management including training in relaxation skills, training in enhancing cognitive coping skills, training in self-hypnosis; assertiveness training, training in problem solving techniques | physical conditioning and work conditioning/simulation | included with behavioral | vocational counseling and placement services | daily over a 4-6 week period; average 25.4 half-days, 3.1 full days | usual care: managed by primary care physician; generally included PT, therapeutic exercise, hand therapy, chiropractic treatment, rehab counseling, and/or pain treatment
Fishbain 2005 ^130^ | treatment directed by neurosurgery, physiatry also part of treatment | biofeedback, psychiatry, psychology | Physical Therapy, occupational therapy, massage therapy; “usually approximately 6 hours per day” of exercise | educational groups | | 30 days, usually half inpatient, half outpatient
Flavell 1996 ^131^ | team included specialist in rehab medicine; education sessions on medical issues | team included psychologist and social worker; relaxation sessions | physical sessions of exercise, hydrotherapy; team included physiotherapist, physical educator, occupational therapist, and recreation officer | team included physical educator; education sessions held on medical issues, fitness, leisure, return to work and pain management | | six weeks, two days per week, 6 hrs per day
France 1991 ^132^ | standardization of medications; trial of epidural steroid blocks and TENS | pain group therapy, instruction in EMG-assisted relaxation techniques, cognitive pain reduction strategies | structured exercise program of stretching and strengthening, hot/cold packs, ultrasound | included with behavioral | | 3 weeks intensive inpatient; continuation with “effective therapeutic modalities (except epidural block and group therapy)” on outpatient basis after discharge
Fricton 1996 ^133^ | Pretreatment assessment by dentist; established physical diagnosis, placed/adjusted a complete stabilization splint if considered appropriate, monitored medications | Psychologist diagnosed psych disturbances and provided appropriate management/referral, educated subjects as to the nature of the psychosocial influences on their pain and offered a cog-behav program designed to change maladaptive behaviors such as clenching, bruxing, sleep, and dietary contributing factors | PT provided exercise program designed to improve jaw and cervical range of motion, function, posture | part of behavioral component | | 6 months; approx 6 × 30 minutes with dentist, once per month with PT, 4 × 1 hour with psychologist
Gagnon 2009 ^134^ | psychological care: “conversations” and relaxation therapy | muscle-strengthening, cardiovascular, active stretching, proprioceptive exercises | information and guidance on physiopathological mechanisms of non-specific CLBP, posture, and ergonomics | contact made with workplace to make appropriate changes to prepare for return to work | 5 weeks, 20 days total
Garcy 1996 ^135^ | same as PRIDE | same as PRIDE | same as PRIDE | same as PRIDE | same as PRIDE | 2-3 week “intensive phase of tertiary care program”
Gatchel 1986 ^136^ | Same as Mayer 1985 spine | cognitive-behavioral treatment orientation | repeated noninvasive testing of back function to steer treatment process | same as Mayer 1985 | | not reported
Gatchel 1986 ^137^ | Same as Mayer 1985 spine | cognitive-behavioral treatment orientation | repeated noninvasive testing of back function to steer treatment process | same as Mayer 1985 | | 3 weeks; 55 hours per week
Gatchel 1994 ^138^ | medication management; pretreatment eval with physician | behavioral stress management training, cog-behav skills training, individ and group counseling emphasizing a crisis intervention model, family counseling | 3-6 weeks home exercises pre-treatment; physical reconditioning and whole-body retraining | cog-behav skills training | | 3 weeks, 57 hrs per week
Gatchel 1999 ^139^ | medically directed treatment program | individual counseling and group therapeutics | quantitively directed exercise progression supervised by PT and OT | education focused on disability management, vocational reintegration, stress management, improvement in coping skills, future fitness maintenance | | 3 weeks
Gatchel 2002 ^140^ | pretreatment eval with physician; medical and medication management | group counseling, individual psych management (multimodal cognitive-behavioral methods of pain mangement)--10-16 sessions | 6-12 PT sessions involving general reconditioning and ROM and strengthening exercises | 10 sessions group counseling involving education about pain issues such as coping, pacing, stress, group social support | | varies
Gatchel 2005 ^141^ | Same as Mayer 1985 spine | individual counseling, group therapeutics, stress management, vocational reintegration, future fitness management | quantitatively directed PT/OT exercise program | same as Mayer 1985 | | 5-7 weeks
Gatchel 2009 ^90^ | not described; referred to Mayer/Gatchel book (1988) | | | | | | Standard treatment in the anesthesia pain clinic at WHMC; includes pain med management, antidepressants, nerve blocks, steroid injections, basic exercise as appropriate
Gatchel 2010 ^142^ | medically directed program; medical assessments; medication management/controlling opioid dependence | cog-behav therapy, individual counseling, group therapeutics, biofeedback | quantitatively directed PT/OT exercise program; future exercise maintenance | education focused on disability management, vocational reintegration, stress management, improvement in coping skills | post-intervention: long-term care plan for maintenance of skills learned in program, controlling opioid dependence, prevention of recurrent disability by expedited management of pain flare-ups | not reported
Glenn 2003 ^143^ | medication management by a physician | individual and group CBT, approx 2 hours per week geared toward decreasing maladaptive thoughts and appraisals of pain and disability, teaching adaptive coping skills | PT and OT approximately 5 hours per day | “education about pain” | | 4 weeks, 5 days/week
Gross 2005 ^144^ | program team includes medicine | treatment includes psychologic interventions, disciplines on treatment team includes psychology | exercise--general and specific to injured body part, work simulation activities, PT, exercise therapy, and OT on the treatment team | treatment includes education | | 4-7 weeks
Guck 1988 ^145^ | medication withdrawal; further description in Guck 1985 | treatment of psychological issues; description in Guck 1985 | graduated increase in physical activity and exercise; description in Guck 1985 | description in Guck 1985 | | 4 weeks
Guck 1999 ^80^ | pain medications gradually tapered and eliminated | psychosocial issues related to or caused by pain were addressed | progressively increasing program of daily exercise | pts taught a variety of pain coping and relaxation skills | | 4 weeks, 5 days per week, all day
Gunreben-Stempfle 2009 ^28^ | education on headache pathophysiology, evidence-based treatment, evaluation, and discussion of triggers once per week for one hour; assessment by a neurologist every 2 weeks to optimize pharmacological therapy | group-based stress management training using a cognitive-behavioral approach once a week for 2 hours; progressive muscle relaxation training twice a week for one hour; weekly supervised biofeedback therapy, psychological one-on-one interview every 2 weeks | group exercise sessions supervised by an exercise therapist twice a week for 2 hours including aerobic exercise, stretching, and light weight training | described in other components | groups of 6-8 pts; assigned to practice relaxation exercises at home every day; after completion of program, opportunity to attend up to 3 sessions in the first year to facilitate transfer to everyday life | 2 times per week for 6 hours each time for a total of 16 treatment days | two different groups from a prior study: a low-intensity pain program of 20 hours duration including education on headache treatments (drug and non-drug) and training in progressive muscle relaxation techniques; the other comparison group was primary care management— non-standardized therapy by primary care physicians. This study took place between 1998 and 2000; the current study was 2004 to 2005
Gustafsson 2002 ^13^ | initial exam by physician; education on pain, medication, sleep; team included rheumatologist and a registered nurse; physician provided medical consultation during course of treatment | treatment team included social workers; education included stress, coping strategies | treatment team included physiotherapists ; relaxation training and fitness training in a warm water pool; BAT: movements during mental awareness used to normalize postural control, coordination, breathing and muscular tension; individual programs for walking and stretching | see other components for details | | 3 full days per week for 3 weeks followed by a return to work with 1 full day of treatment every other week for 5 more occasions | waiting list: pts continued whatever treatment they were already doing
Hatten 2006 ^146^ | initial evaluation by physician, treatment plan, meds management | “psychological management” | physical therapy sessions | “group education” | note: program not well-described in this article, which focuses on cost-utility analysis | median MPP completion = 5 months, 23 days | not well-described; non-MPP pts received a treatment plan recommendation, but no info on what that included or whether it was pursued
Hazard 1989 ^147^ | modeled after PRIDE; initial clinical evaluation | stress management program monitored by biofeedback, behavioral skills training in assertiveness, rational emotive therapy, pain-related crisis mgmt; daily group therapy, alternate-day individual therapy, weekly family meetings | 2 daily sessions of “floor exercises” including stretching and dynamic strengthening; progressive weight training and general endurance and coordination training; OT including work hardening | daily didactic programs covering spinal anatomy, medications, compensation law, surgery, and the theoretical foundations of the treatment | | 3 weeks, 53 hrs per week | no treatment through NEBC for “denied” group; crossover group included 6 pts initially denied coverage who were treated 6 mos later
Hazard 1991 ^148^ | modeled after PRIDE; initial clinical evaluation | stress management program monitored by biofeedback, behavioral skills training in assertiveness, rational emotive therapy, pain-related crisis mgmt; daily group therapy, alternate-day individual therapy, weekly family meetings | 2 daily sessions of “floor exercises” including stretching and dynamic strengthening; progressive weight training and general endurance and coordination training; OT including work hardening | daily didactic programs covering spinal anatomy, medications, compensation law, surgery, and the theoretical foundations of the treatment | | 3 weeks, 53 hrs per week
Hazard 2009 ^149^ | modeled after PRIDE; initial clinical evaluation by medical physician or nurse practitioner | stress management program monitored by biofeedback, behavioral skills training in assertiveness, rational emotive therapy, pain-related crisis mgmt; daily group therapy, alternate-day individual therapy, weekly family meetings | 2 daily sessions of “floor exercises” including stretching and dynamic strengthening; progressive weight training and general endurance and coordination training; OT including work hardening | daily didactic programs covering spinal anatomy, medications, compensation law, surgery, and the theoretical foundations of the treatment | | 3 weeks, 8 hrs per day
Hildebrandt 1997 ^150^ | physical assessment by a physician | cognitive-behavioral group therapy, relaxation training; goal to change maladaptive behavior, alter maladaptive cognitions, improve coping skills, counteract depression, etc. | pre-program period of stretching and callisthenic exercises; intensive treatment period included aerobic, functional strength and endurance exercises | back school, pre-program education | 3-week pre-program period of education and light activity, 4 hours per day, 3 days per week | intensive, multidisciplinary treatment of 5 weeks, 7 hours per day
Hooten 2007 ^19^ | Discontinuation or reduction in benzodiazepines, muscle relaxants, and analgesics (including opioids) initiated and coordinated by a physician after admission (unless meds were being used to treat comorbid medical or psych illnesses); pre-admission physician exam | cognitive-behavioral model served as basis for treatment, including biofeedback, relaxation training, stress management, and elimination of pain behaviors | daily PT with increased intensity over course of program; daily OT addressing impairments of ADLs | Chemical health education, daily cognitive-behavioral group educational sessions | | 3 weeks, 8 hrs per day, 5 days per week
Hooten 2009 ^151^ | Discontinuation or reduction in benzodiazepines, muscle relaxants, and analgesics (including opioids) initiated and coordinated by a physician after admission (unless meds were being used to treat comorbid medical or psych illnesses); pre-admission physician exam | cognitive-behavioral model served as basis for treatment, including biofeedback, relaxation training, stress management, and elimination of pain behaviors | daily physical reconditioning | Chemical health education, daily cognitive-behavioral group educational sessions | | 3 weeks, 8 hrs per day, 5 days per week
Hooten 2009 ^152^ | Discontinuation or reduction in benzodiazepines, muscle relaxants, and analgesics (including opioids) initiated and coordinated by a physician after admission (unless meds were being used to treat comorbid medical or psych illnesses); pre-admission physician exam | cognitive-behavioral model served as basis for treatment, including biofeedback, relaxation training, stress management, and elimination of pain behaviors | daily PT with increased intensity over course of program; daily OT addressing impairments of ADLs | Chemical health education, daily cognitive-behavioral group educational sessions | | 3 weeks
Howard 2009 ^153^ | medically supervised | disability management such as counseling stress management, biofeedback, coping skills | quantitatively-directed exercise progression under supervision of PT/OT | education support and assistance provided for injury prevention and occupational factors | | not reported
Huge 2006 ^154^ | assessment by an evaluation group including physicians (anesthesiologists, physical medicine and rehab); education provided on anatomy and biomechanic principles of the spine, pain physiology, and pharmacology of analgesics and other meds used in pain treatment | cognitive-behavioral group therapy; progressive muscle relaxation training, education on psychological factors of pain perception | training program for improvement of force, endurance, and coordination, including swimming, aerobics, sauna, functional strength and endurance exercise; posture and ergonomic movements taught and trained with simulated workstations (work hardening) | see medical and behavioral component descriptions | offered in groups of 6-8 pts | 4 weeks, 5 days per week, 8 hours per day | 60-90 minute assessments by a physician and a psychologist; therapeutic plan created, including physical therapy, psychological intervention, and relaxation; implementation of the proposed therapy was left “to the discretion of the patient and his primary care physician”
Jensen 1995 ^155^ | staff included physicians and nurses; education included anatomy, medications, etc.; medication cessation where appropriate | group cognitive-behavioral intervention led by a psychologist, including teaching and practicing pain and stress coping skills; taught about pain behavior and the role of secondary gains | PTs led group progressive relaxation class; physical exercise, TENS, hot/cold packs, mobilization, etc. | series of lectures on topics described in other components | | 5 weeks | same as MPP, except no behavioral component
Jensen 1994 ^156^ | team included physician and nurse; education included anatomy, use/effect of medications, pain behavior and its consequences, etc. | cognitive-behavioral module of 8 sessions on problem solving, goal setting, acquisition of skills, and relaxation are taught and practiced; contract developed with goals of behavioral changes to enhance health-promoting behavior; treatment team included a psychologist | designed to enhance endurance more than strength; progressive training plus physical activity (walking, swimming, bowling, etc.); led by PTs; some pts were offered passive exercises, ultrasound, heat, massage, etc. | 12 lectures given by all members of the treatment team; see other components | One day training program for pts' supervisors | 8 hrs per day, 4 weeks | sicklisted workers living in the area; no treatment
Jensen 1998 ^157^ | team included physician and nurse; education included anatomy, use/effect of medications, pain behavior and its consequences, etc. | cognitive-behavioral module of 8 sessions on problem solving, goal setting, acquisition of skills, and relaxation are taught and practiced; contract developed with goals of behavioral changes to enhance health-promoting behavior; treatment team included a psychologist | designed to enhance endurance more than strength; progressive training plus physical activity (walking, swimming, bowling, etc.); led by PTs; some pts were offered passive exercises, ultrasound, heat, massage, etc. | 12 lectures given by all members of the treatment team; see other components | One day training program for pts' supervisors | 8 hrs per day, 4 weeks | sicklisted workers living in the area; no treatment
Jensen 1992 ^158^ | same as Jensen 1994 | same as Jensen 1994 | same as Jensen 1994 | same as Jensen 1994 | same as Jensen 1994 | same as Jensen 1994
Jensen 1994 ^159^ | initial clinical exam; opioid and sedative-hypnotic tapering as needed | individual and family psychotherapy; group coping skills training | PT and OT | group pain education | | 3 weeks
Jensen 2001 ^160^ | initial clinical exam; opioid and sedative-hypnotic tapering as needed | individual cognitive-behavioral psychotherapy; group coping skills training | quota-based physical and occupational therapy | group pain education | | 3 weeks, 5.5 days per week (some pts--20% of this cohort--stay longer if they “require additional time to reach maximum gains and have funding for additional time; most of these complete 4 weeks rather than 3)
Jensen 2003 ^14^ | UW: clinical assessment, medication management (focus on decreasing and eliminating use of sedatives and opioids) FM: tapering of opioid and sedative-hypnotics when appropriate, initial clinical assessment by rheumatologist | UW: individual cognitive-behavioral psychotherapy; group coping skills training FM: cognitive-behavioral therapy | UW: PT and OT focused on increasing strength, flexibility, endurance, and sitting/standing time and assisting the pt to return to customary work, household, and avocational activities FM: Physiotherapy, occupational therapy | UW: group pain education FM: “education” | | UW: 3-weeks, 5.5 days per week FM: 4 weeks, 5 days per week
Jensen 2004 ^17^ | UW: clinical assessment, medication management (focus on decreasing and eliminating use of sedatives and opioids) FM: tapering of opioid and sedative-hypnotics when appropriate, initial clinical assessment | UW: individual cognitive-behavioral psychotherapy; group coping skills training FM: cognitive-behavioral therapy | UW: PT and OT focused on increasing strength, flexibility, endurance, and sitting/standing time and assisting the pt to return to customary work, household, and avocational activities FM: Physiotherapy, occupational therapy | UW: group pain education FM: “education” | UW: Pt. family members asked to participate during last two days FM: weekly one-hour educational sessions for family members | UW: 3-weeks, 5.5 days per week FM: 4 weeks, 5 days per week
Jensen 2007 ^161^ | initial clinical exam; opioid and sedative-hypnotic tapering as needed | individual cognitive-behavioral psychotherapy; group coping skills training | quota-based physical and occupational therapy | group pain education | Pt. family members asked to participate during last two days | 3 weeks, 5.5 days per week
Jousset 2004 ^162^ | initial assessment with physiatrist, occupational medicine specialist; weekly meetings with physiatrist (medical supervisor of the program) | initial appointment with psychologist, further appointments scheduled “if required” | daily group physical activity including: stretching, proprioception, strengthening exercises, aerobic activities, endurance training, balneotherapy; daily occupational therapy including training in flexibility, endurance and coordination, weight lifting, and work simulation | ergonomics | | 5 weeks, 5 days per week, 6 hours per day | Active individual physical therapy sessions: 1 hr treatment sessions, 3 times per week, for 5 weeks; program of exercise to be performed at home on two additional days per week
Kaapa 2006 ^163^ | rehab team included rehabilitation medicine physician; back school included 4 hours instruction from physician; “if necessary” medications were prescribed or changed; individual physiatrist appointment to explain imaging findings and clarify causes of back pain (and review meds) | cog-behav stress management methods and applied relaxation (10 hours total) | PT and occupational PT taught total of 11 hours of back school; instruction in work ergonomics, including review of videotape of patients in workplace; physical exercise program planned individually based on PT exam and baseline fitness, endurance, and mobility; program carried out in groups including general fitness, muscle strengthening, spine and hip mobility, functional exercises, and progressive relaxation | back school including anatomy, functions of muscles and spine, active treatment methods | home-exercise period | 8 weeks comprising 70 hours of treatment: intensive period of 5 days/6 hrs per day; home-training of 2 weeks, and semi-intensive period of 5 weeks/two days per week/2 hours per session | individual PT: 10 one-hour treatment sessions over 6 to 8 weeks; each session included 30- to 40-minutes of passive pain treatment (massage, traction, manual mobilization of spine, TNS) and 15- to 20-minutes of light active exercise (muscle stretching, spine mobilization, deep trunk muscle exercises); light home-exercise program; encouraged to do general physical training (swimming, walking)
Kenny 2004 ^164^ | supervised reduction/withdrawal of pain medications; medical consultations | cognitive-behavioral program; psychological consultations | exercise, group activities, community-based tasks; functional restoration program | education sessions | study tested addition of group singing lessons to the normal ADAPT program | 3 weeks, 5 days per week, 8 hrs per day
Keogh 2005 ^165^ | treatment team includes nurse, physicians | treatment based on Acceptance and Commitment Therapy; included relaxation exercises, exposure to thoughts and feelings related to the experience of pain, etc.; daily psychology and relaxation sessions; no direct cognitive restructuring exercises | graded exposure and activation of the whole body in group sessions twice daily | health habits and choosing meaningful directions in life; also included with behavioral | group delivered | 3 or 4 weeks residential or 3 weeks in-hospital; 5 days per week, 6 hours per day
Kidner 2009 ^166^ | medically supervised | disability management such as counseling stress management, biofeedback, coping skills | quantitatively-directed exercise progression under supervision of PT/OT | education support and assistance provided for injury prevention and occupational factors | | not specified
Kleinke 1988 ^167^ | medicine and nursing disciplines | relaxation, social work, group therapy | TENS, PT, massage, heat, ice | lectures | | 28 days
Kohles 1990 ^168^ | medically supervised | disability management such as counseling stress management, biofeedback, coping skills | quantitatively-directed exercise progression under supervision of PT/OT | education support and assistance provided for injury prevention and occupational factors | later group received “more aggressive rehabilitation and reconditioning philosophy” and an expanded pre-treatment education phase | 3 weeks + pretreatment phase of 2-6 weeks for later group
Kole-Snijders 1999 ^169^ | initial screening exam by physician; medication management | treatment contract created based on baseline activities and pain behaviors for increasing activity and decreasing pain behavior; weekly sessions with psychologist; In addition, there were three different cognitive portions:; 1. cognitive coping skills training program with a behavior therapist delivered in groups; 2. an attention control to compare with the first condition: group discussion program led by the same behavior therapist using a book about pain written for pain patients plus group listening to music; EMG biofeedback was demonstrated once in this condition; 3. no additional cognitive portion; this condition was less standardized and did not include the contract or the spouse training (see “other MPP components”)--this was considered Operant Behavioral treatment as usual and was provided individually, rather than in groups | 50 hrs of individual physical therapy, 38 hours of group PT; 12 hrs of individual OT, 26 hrs of group OT | as part of the Operant Behavioral treatment model, pts are taught the difference between health behavior and pain behavior | In conditions other than Operant Behavioral Treatment as usual: weekly spouse group training using operant behavioral treatment; treatment delivered in groups | 2 weeks pre-treatment recording of baseline activities; 5 weeks inpatient treatment, 3 weeks outpatient treatment 3 days per week | Wait-list period of no treatment (after wait-list period, these patients were provided the Operant Behavior Treatment as usual)
Koopman 2004 ^170^ | team included occupational physician | team included psychologist; group and individual counseling using cognitive therapy; one individual counseling session per week; relaxation training twice a week | team include physical therapist and physical education instructor; physical reconditioning on the Graded Activity principle following an operant conditioning approach plus graded exposure following a classical conditioning approach; physical fitness training, functional training, recreation, hydrotraining, stretching | training in relaxation for pain control, etc. | partner/significant other program of three meetings; most content delivered in groups of 6-10 pts | 12 weeks, 3 sessions per week, 6 hrs per day
Lang 2003 ^171^ | providers included a physician, who provided education components | 1 hour per session of cognitive-behavioral therapy; included group and individual counseling; 0.5 hours of progressive muscle relaxation training provided by psychologist | 1.5 hours per session of “restorative exercise therapy” conducted and supervised by one of the sport teachers, 0.5 hours of individual physiotherapy | 0.5 hours per session of education on anatomy, physiology, and movement-related basics of the back and evidence-based knowledge about the effectiveness of back-related therapies | program organized “by cooperation of local health-care providers in the community with different specialties who were experienced in the management of back pain”; cost was 600 DM (this was in 1997-98) and was paid for by the patient | 20 days at the rate of 3 days per week, 4 hours per day | usual care provided by 35 community physicians and physiotherapists
Law 2009 ^172^ | drug reduction | relaxation, sleep management, family involvement | exercise and stretch, pacing, at least 3 hours daily of physical rehab | education on behavioral modifications and other issues | stretching of one hamstring, but not the other | 3 weeks
Lipchik 1993 ^48^ | medications and detoxification from addictive medications | biofeedback training, assertiveness training, individual, family, and group psychotherapy, behavior modification, psychoeducational group therapy, stress management training | physical exercise program, OT | psychoeducational group therapy | | 3-4 weeks | variety of outpatient treatments, but no psychotherapy (most frequent was 41% prescribed antidepressants, 35% received nerve blocks or trigger point injections, 17% referred for PT, 19% referred for biofeedback)
Luoto 1996 ^173^ | baseline medical exam by physiatrist, team carrying out program included physician | cognitive-behavioral disability management groups (relaxation, visual images, etc.) | cardiovascular endurance exercises, muscular strength and endurance exercises, stretching; no passive PT | 5 hours of discussion groups per week including improving skills to cope with pain, problem solving, etc. | included group therapy (no info on group size) | 3 weeks home-based exercise post-baseline exam; 3 weeks inpatient, 42+ hours per week
Luoto 1998 ^174^ | baseline medical exam by physiatrist, team carrying out program included physician | cognitive-behavioral disability management groups (relaxation, visual images, etc.) | cardiovascular endurance exercises, muscular strength and endurance exercises, stretching; no passive PT | 5 hours of discussion groups per week including improving skills to cope with pain, problem solving, etc. | included group therapy (no info on group size) | 3 weeks home-based exercise post-baseline exam; 3 weeks inpatient, 42+ hours per week
Lynch 1996 ^175^ | physician monitoring (e.g., medication management) | individual, family, group psychosocial treatment sessions (stress management, communication skills, etc.) | physical exercise programming, OT, individual and group vocational rehab counseling, recreational therapy | part of psychological component: differences between chronic and acute pain, role of psychological factors in modulating pain, benefits of pacing and other modifications in behavior | admitted as a group of 3-4 | 6 weeks: one week of assessments and goal setting, 5 weeks of full-day sessions | no treatment from center or didn't complete program
Maclaren 2006 ^176^ | “medical management was also included” | psychoeducation in a group format included information on pain-coping skills and other health-related information; individual training in self-management techniques (e.g., progressive muscle relaxation) | PT and OT including stretching, strength training, cardiovascular training, and work conditioning/hardening | included in behavioral | | 4-6 weeks, 5 days per week, 6 hours per day; 3 hrs PT/OT, 3 hrs psycho-education each day
Magnusson 2004 ^27^ | assessment and medical follow-up by neurologist; symptomatic medications for headache; advice available from nursing coordinator | group therapy including self-management group on pain-coping strategies; some optional groups available as well, including sleep, relaxation, family, and “rebuilding self and relationships” | instruction in posture and exercise by a kinesiologist; physiotherapy as considered appropriate by the program PT and physician | lectures on pain-related topics for pts and families | | average 11 mos (range 2-22 mos) | usual care: physician-based pharmacological program with neurologist, generally seen every 3-5 months; written information appropriate to situation, counseling and education from a nurse
Man 2007 ^177^ | staff includes pain nurses and a pain specialist | staff includes clinical psychologist and medical social worker, training in communication skills and coping strategies, setting goals, pacing, relaxation | graded physical exercises, functional activities training, team includes OT and PT, walking, stretching, personal exercise training | teaching sessions from all clinic staff on pain mechanisms and management | | 14 full days over the course of 6 weeks
Mangels 2009 ^178^ | medical care including analgesic medication if necessary | cognitive-behavioral group on psychologic pain management guided by a manual, included handouts on biopsychosocial model of pain, pain coping strategies, etc.; progressive muscle relaxation training, weekly individual sessions with the psychotherapist | physical therapy in individual and group sessions, occupational therapy with ergonomic training, art therapy, etc.; massage, electrotherapy, hydrotherapy, thermotherapy, nutritional advice | back school, see behavioral component | some patients were also offered 7 Booster sessions conducted by telephone by clinical psychologists | 4 weeks | orthopedic rehabilitation treatment on inpatient basis--similar to the treatment described for MPP, except offered in a more individualized context (less group content) and NO behavioral component except for optional training in progressive muscle relaxation
Maruta 1990 ^179^ | Medication management, complete medical evaluation at admission | cognitive/operant conditioning, group psychotherapy, biofeedback-relaxation, supportive psychologic treatment | physical rehabilitation measures | “education”: further described in three Swanson et al. publications | pts with provisional chemical dependency diagnoses are directed to participate in daily chemical dependency group; key goal of treatment is to “reduce the intake of medication to a minimum” | variable; mean for first 249 completers was 23 days
Masuda 2005 ^40^ | minimization of drugs, injection, and cataplasm | CBT targeting pain -related cognition and behavior | exercise therapy | education in pain-related beliefs and connection to chronic pain, psychosocial factors, etc. | half of patients also received thermal therapy in a far-infrared ray dry sauna system | 5 weeks
Mayer 1994 ^180^ | initial assessment by physician | group/individual counseling | 6 hrs per day of aggressive physical training | 4 hrs per day of group/individual counseling or educational classes | initial phase of 4-hrs per week pre-admission for education and stretching/strengthening ; post-phase of average 25 further hours of supervised training (range 5 to 40 hrs) | 3-week intensive phase, 10 hrs per day
Mayer 1998 ^75^ | no info provided, assumed same as other post-1987 PRIDE
Mayer 2001 ^181^ | initial assessment by physician; drug detoxification as necessary | group/individual counseling on work return, coping, pain management skills, and stress management | strength and endurance training supervised by PT/OT | education focused on psychosocial and case management factors | | not specified
Mayer 2006 ^182^ | initial assessment by physician | group/individual counseling on work return, coping, pain management skills, and stress management | quantitatively directed strength and endurance training supervised by PT/OT | education focused on psychosocial and case management factors | | not specified
Mayer 1986 ^183^ | medically directed, clinical exam at admission | behavioral pain management training (muscle relaxation, guided imagery, EMG/temperature biofeedback); cognitive-behavioral skills training; individual and group counseling on crisis-intervention; family counseling | exercises to enhance spinal mobility, trunk strength, endurance, CV fitness, lifting capacity, positional tolerance, work simulation/hardening | training and education as part of physical rehabilitation | | 3 weeks, 58 hours per week | 3-week inpatient program involving medical treatment, PT, OT, psychological treatment including biofeedback and behavioral intervention; different follow-up time period (11-15 months), no physical data
Mayer 1987 ^184^ | medically directed, clinical exam at admission | behavioral pain management training; cognitive-behavioral skills training; individual and group counseling on crisis-intervention; family counseling | exercises to enhance spinal mobility, trunk strength, endurance, CV fitness, lifting capacity, positional tolerance, work simulation/hardening | training and education as part of physical rehabilitation | | 3-weeks; 57 hours per week | no treatment provided by PRIDE group
Mayer 1988 ^185^ | initial assessment by physician | multimodal disability management approach using cognitive-behavioral techniques | physical training and work simulation based on quantified physical functional capacity | includes 50% education/counseling | | 2 or 3 weeks, 53 hours per week; 50% physical training, 50% education/counseling
Mayer 2002 ^186^ | initial assessment by physician; drug detoxification as necessary | group/individual counseling on work return, coping, pain management skills, and stress management | strength and endurance training supervised by PT/OT | education to maintain program goals including fitness maintenance, vocational counseling, etc | | not specified
Mayer 2008 ^187^ | medically directed, clinical exam at admission | behavioral pain management training; cognitive-behavioral skills training; individual and group counseling on crisis-intervention; family counseling | quantitatively directed strength and endurance training supervised by PT/OT | education focused on disability management, vocational reintegration, stress management, improvement in coping skills | narcotic detoxification | 4-10 weeks; dependent on other responsibilities, with daily treatment preferred; intensive phase usually attended 8 h/d
McCracken 2005 ^188^ | treatment team includes nurse, physicians | treatment based on Acceptance and Commitment Therapy; included relaxation exercises, exposure to thoughts and feelings related to the experience of pain, etc.; daily psychology and relaxation sessions; no direct cognitive restructuring exercises | graded exposure and activation of the whole body in group sessions twice daily | health habits and choosing meaningful directions in life; also included with behavioral | group delivered | 3 or 4 weeks residential or 3 weeks in-hospital; 5 days per week, 6 hours per day
Michaelson 2004 ^189^ | preliminary medical exam by physician; treatment team included physician | treatment team included psychologist; behavioral group therapy and relaxation exercises | physical exercise aimed at improving general fitness and increasing physical capacity of specific body regions; treatment team included PTs | treatment included back school | after inpatient portion, pts given individual one-year rehab programs to perform on their own; two further meetings with treatment team at 3 mos and 12 mos | 4 weeks, 5 days per week, 6 hours per day
Middaugh 1988 ^190^ | medical management including diagnostics and withdrawal from narcotics | biofeedback, pacing, cognitive coping techniques, stress management techniques, communication skills | extensive daily exercise, walking, stationary cycling; OT including use of proper posture and body mechanics | included with behavioral | | inpatients: 3-4 weeks; outpatients: 4 hours per week for 8 weeks
Mohler 1991 ^191^ | dental treatment | biofeedback with psychological counseling; substance abuse education; pain management education | PT and OT; flexibility/condit ionings/strengt hening exercises, body mechanics education; supervised occupational, recreational, and social activities | “psychoeducational classes designed to be appropriate for individuals with various MSK injuries” | groups of up to 10 patients--none of the other pts in the groups would have had craniomandibular disorder | 4 weeks, 5 days per week, 8+ hours per day
Moore 1986 ^24^ | initial eval by neurosurgeon to r/o immediate need for surgery or other biomed treatments; gradual withdrawal of pain meds | “treatment was based on cognitive-behavioral principals”; individual, marital, and group psychotherapy; training in cognitive pain management techniques; relaxation training | exercise in a heated pool; physical therapy, occupational therapy | training included cognitive pain management, relaxation | spouses trained in operant techniques to reinforce health behaviors and extinguish pain behaviors | average 6 weeks
Norrefalk 2005 ^192^ | initial meeting with rehab medicine specialist physician or physician in specialist training for 1.5 hours; pain school run by physician; treatment team included several physicians and a nurse; minimization of drugs during first 3 weeks of treatment | treatment team included psychologist and social counselor; psychological pain management, group counseling, relaxation groups, family meetings | physical, functional, and ergonomic training; treatment team included 3 PTs and 3 OTs; OT visit to employer, if any; individual exercise programs designed for all pts to increase physical function (including cycling, walking, pool, stretching, TENS, hot packs, etc.) | pain school, various training in ergonomics, etc. (see other components) | First 3 weeks constituted an Impairment and Disability Evaluation and Analysis (IDEA) to assess possible work ability in spite of and considering the pts' remaining pain situation | 8 weeks, 5 days per week, 7.5 hours per day | pts rejected for lack of space
Norrefalk 2006 ^193^ | initial meeting with rehab medicine specialist physician or physician in specialist training for 1.5 hours; pain school run by physician; treatment team included several physicians and a nurse; minimization of drugs during first 3 weeks of treatment | treatment team included psychologist and social counselor; psychological pain management, group counseling, relaxation groups, family meetings | physical, functional, and ergonomic training; treatment team included 3 PTs and 3 OTs; OT visit to employer, if any; individual exercise programs designed for all pts to increase physical function (including cycling, walking, pool, stretching, TENS, hot packs, etc.) | pain school, various training in ergonomics, etc. (see other components) | First 3 weeks constituted an Impairment and Disability Evaluation and Analysis (IDEA) to assess possible work ability in spite of and considering the pts' remaining pain situation | 8 weeks, 5 days per week, 7.5 hours per day
Norrefalk 2007 ^194^ | Same as Norrefalk 2005 | Same as Norrefalk 2005 | Same as Norrefalk 2005 | Same as Norrefalk 2005 | Same as Norrefalk 2005 | 8 weeks, 7.5 hrs per day, 5 days per week | N/A
Norrefalk 2008 ^195^ | initial meeting with rehab medicine specialist physician or physician in specialist training for 1.5 hours; pain school run by physician; treatment team included several physicians and a nurse; minimization of drugs during first 3 weeks of treatment | treatment team included psychologist and social counselor; psychological pain management, group counseling, relaxation groups, family meetings | physical, functional, and ergonomic training; treatment team included 3 PTs and 3 OTs; OT visit to employer, if any; individual exercise programs designed for all pts to increase physical function (including cycling, walking, pool, stretching, TENS, hot packs, etc.) | pain school, various training in ergonomics, etc. (see other components) | First 3 weeks constituted an Impairment and Disability Evaluation and Analysis (IDEA) to assess possible work ability in spite of and considering the pts' remaining pain situation | 8 weeks, 5 days per week, 7.5 hours per day | treatment as usual
Olason 2004 ^196^ | treatment team includes physicians and nurses; first two weeks are dedicated to education, including physiology; pain-relieving drugs are discontinued | treatment team includes psychologist and social worker; pts are evaluated for psychosocial factors and “problems are dealt with as necessary”; body awareness training and relaxation techniques taught individually and in groups | treatment team includes OTs, PTs and sports therapists; education portion includes ergonomics; after first two weeks, emphasis is on physical fitness, mostly offered in groups (“most of the patients have already received physical therapy and do not get individual physical therapy”; some do get manipulation or other forms of “special physical therapy” | first two weeks of program are “pain school”: see other components for description | | 7 weeks
Patrick 2004 ^197^ | inpatient program at a hospital; medications monitored to allow only aspirin and Tylenol | operant conditioning on exercise behaviors, relaxation training, biofeedback training, cognitive-behavioral coping skills, daily homework exercises | twice-daily PT and daily aerobic fitness | daily education on mechanisms of pain; vocational rehab | | 3 weeks inpatient | same as MPP EXCEPT behavioral component (not provided)
Perry 2010 ^77^ | education about pain mechanisms, medication management with program physician, education on potential signs that changes in pain level may represent a serious medical condition | training in self-management skills such as relaxation and desensitization, goal setting, cognitive restructuring, communication | pacing and upgrading of activities, exercise, stretch | included with medical and behavioral | used Manage Your Pain book; delivered in groups | 10 group sessions totaling 45 hours of contact time | Usual care: included medications, individual PT and clinical psychology interventions for pain management, implantation of intrathecal pumps, etc.
Pfingsten 1997 ^74^ | physical assessment by a physician | cognitive-behavioral group therapy, relaxation training; goal to change maladaptive behavior, alter maladaptive cognitions, improve coping skills, counteract depression, etc. | pre-program period of stretching and callisthenic exercises; intensive treatment period included aerobic, functional strength and endurance exercises | back school, preprogram education | 3-week pre-program period of education and light activity | 5 weeks, 7 hours per day
Polatin 1989 ^198^ | same as prior | same as prior | same as prior | same as prior | | not noted
Polatin 1997 ^199^ | medically supervised | cognitive-behavioral classes, individual and group counseling | preparatory phase of preconditioning mobility, intensive phase for strength and endurance | structured patient education | | 2-3 weeks intensive (10 hrs per day, every day); 2-6 weeks preparatory (meeting twice per week)
Proctor 2004 ^200^ | drug detox, medically supervised program | psychological and case management techniques | quantitatively directed exercise progression | geared toward fitness maintenance | | 3-week intensive plus variable length pretreatment phase of physical preparation and education
Proctor 2005 ^201^ | drug detox, medically supervised program | psychological and case management techniques | quantitatively directed exercise progression | geared toward fitness maintenance | | not described
Protas 2004 ^202^ | drug detox, medically supervised program | psychological and case management techniques | quantitatively directed exercise progression | geared toward fitness maintenance | | total of 5-8 weeks including 3 week intensive portion
Rainville 1992 ^203^ | ? Possibly PRIDE program | psychological and behavioral support | aggressive physical conditioning directed by PT and OT for 6 h/day | education about pain-related issues | disability case management | 4-10 weeks, average 7 weeks culminating in all cases with 15 consecutive weekdays of comprehensive therapy during which pts were at the treatment facility for 8 h each day | drop outs from program, pts who went through initial assessment but decided not to enroll
Rainville 1993 ^204^ | ? Possibly PRIDE program | psychological and behavioral support | aggressive physical conditioning directed by PT and OT for 6 h/day | education about pain-related issues | disability case management | 4-10 weeks, average 7 weeks culminating in all cases with 15 consecutive weekdays of comprehensive therapy during which pts were at the treatment facility for 8 h each day | drop outs from program, pts who went through initial assessment but decided not to enroll
Robbins 2003 ^38^ | intake clinical assessment by staff pain physician; all patient treatment plans are discussed by the entire treatment team (including physicians) at initial evaluation, midpoint, and discharge (average: 2-4 physician visit sessions for pt) | individual cognitive-behavioral sessions; pts with complicated psychological distress also referred for 1+ appointments with team psychiatrist for psychotropic meds stabilization (average: 10 individ cog-behav sessions, 1 family session, 1-2 psych meds monitoring sessions) | average 5-10 physical therapy sessions per pt | group educational sessions (average 10 per pt) | | not described | same as MPP except no PT at interdisciplinary program (no info on whether pts received PT elsewhere)
Rome 2004 ^205^ | Discontinuation or reduction in opioids initiated and coordinated by a physician after admission | cognitive-behavioral model served as basis for treatment, including biofeedback, relaxation training, stress management, and elimination of pain behaviors | physical reconditioning, OT for job, leisure, and home activities | Chemical health education, pain management training | | 3-week “intensive”
Sanders 1993 ^26^ | pain med withdrawal and medication management; 6-8 lumbar blocks | individual and group psychotherapy, vocational evaluation and counseling | activity reinforcement and stabilization; active and passive PT | “patient education”
Scerri 2006 ^206^ | individually tailored pharmacotherapy and regular follow-up by a physician | individual and group psychosocial interventions (1.5 hrs per week) | physical therapy (7.5 hrs per week) with stretching, muscle strengthening, and aerobic endurance exercises, occupational therapy (8 hrs per week) | group classes (2.5 hrs per week) | | 3 weeks
Scharff 1994 ^25^ | therapeutic instruction from a neurologist on headaches and treatments | posture correction instruction, ergonomics, muscle relaxation, autogenic training, instruction in basic principles of cognitive therapy | PT instruction in cervical anatomy, neck and should exercises, use of heat and ice | all other components were “headache education and therapeutic instruction” including pathophysiology, nutrition, etc. | | five weekly 3-hour group sessions | no treatment from center
Skinner 1990 ^207^ | staff included anesthetist and a GP who taught autohypnosis; education on gate control theory of pain | staff included two clinical psychologists; pts taught cognitive skills to deal with stress and pain; lifestyle planning group sessions to develop individual goals in areas of paid work, self care, analgesic reduction, and social life; 30 minutes of learning progressive relaxation | staff included a PT; each session included 1 hour physical exercise designed to improve general fitness and confidence in performance of physical activity | included with other components (skills training and education on pain) | when possible, close friends or relatives were included in the lifestyle planning group sessions; delivered in groups of approx 9 | one afternoon per week for 7 consecutive weeks
Skouen 2002 ^208^ | initial clinical exam, education on anatomy and pain mechanisms | cognitive behavioral modification in group sessions | individually based graded exercise program based on physical tests (exercising 1.5 to 3.5 hours per day) | education sessions included exercise, mental coping strategies, fear avoidance, etc. | | 4 weeks, 5 days per week, 6 hours per day | treatment as usual, light multidisciplinary treatment (not everyone got psycho treatment, mostly PT and nurse sessions of education)
Skouen 2006 ^29^ | initial clinical exam, education on anatomy and pain mechanisms | cognitive behavioral modification in group sessions | individually based graded exercise program based on physical tests (exercising 1.5 to 3.5 hours per day) | education sessions included exercise, mental coping strategies, fear avoidance, etc. | | 4 weeks, 5 days per week, 6 hours per day | treatment as usual, light multidisciplinary treatment (not everyone got psycho treatment, mostly PT and nurse sessions of education)
Snow 1988 ^209^ | medication management | group, individual, and family psychotherapy; stress management; hypnosis | PT and OT | stress management workshops, e.g. | vocational counseling | 3 week hospital admission plus average 6 months outpatient “regularly scheduled” appointments
Snow 1990 ^210^ | clinical assessment preadmission | psychotherapy, psychosocial training in time management, leisure planning, and assertiveness; medication management; biofeedback training | general conditioning exercises, strengthening, stretching, connective tissue massage, pool therapy, weight-reduction diet; OT program including activities of daily living training | included in behavioral and PT | | not reported
Spinhoven 2004 ^211^ | initial screening exam by physician; medication management | treatment contract created based on baseline activities and pain behaviors for increasing activity and decreasing pain behavior; weekly sessions with psychologist; In addition, there were two different cognitive portions:; 1. cognitive coping skills training program with a behavior therapist delivered in groups; 2. an attention control to compare with the first condition: group discussion program led by the same behavior therapist using a book about pain written for pain patients plus group listening to music; EMG biofeedback was demonstrated once in this condition | 50 hrs of individual physical therapy, 38 hours of group PT; 12 hrs of individual OT, 26 hrs of group OT | as part of the Operant Behavioral treatment model, pts are taught the difference between health behavior and pain behavior | weekly spouse group training using operant behavioral treatment; treatment delivered in groups | 2 weeks pretreatment recording of baseline activities; 5 weeks inpatient treatment, 3 weeks outpatient treatment 3 days per week | Wait-list period of no treatment (after waitlist period, these patients were provided the Operant Behavior Treatment as usual)
Stans 1989 ^212^ | treatment team included anesthesiologist ; patients taught about gate-control concepts of pain | most clinical contact during inpatient week was conducted by two clinical psychologists, participation from a psychiatrist; relaxation and sensory awareness skills, controlled breathing techniques, imagery and mental activity strategies as methods of coping with pain and stress; training in cognitive restructuring | physical therapy to stretch and strengthen debilitated muscles by general mobilization exercises; clinical team included a psychomotor therapist and several physiotherapists | informal lecture discussion on pain theory, medications, training in coping skills | based on manual from Turk et al. (cognitive-behavioral treatments for pain) | 3 individual pretreatment sessions to learn about treatment approach and gain pt buy-in to therapy; 1 week inpatient treatment; 6 mos outpatient follow-up treatment
Sterner 2001 ^213^ | examined by interdisc team including physician | “programme contained both cognitive and behavioural elements”; team included social worker/psychologist | physical activity including hydrotherapy, body awareness therapy, relaxation | ergonomics, education in pain, pharmacology, stress, and psychological consequences of pain | Mostly group-based, some individual sessions | 5 weeks, 3 days per week at one clinic; 8 weeks, 2 days per week at other
Storro 2004 ^214^ | evaluated at intake by physical medicine specialist | group meetings with MD, PT, and psychologist to “develop greater insight into the process of pain perception, more self-confidence, reduction of fear-avoidance behavior, and greater skills to cope with pain reduction” | physical exercises tailored to individual in intensity and dose | 4 hours education on “mechanisms of pain perception and how pain can be influenced by psychological and behavioural factors in ways that can be self-reinforcing and thus account for a complex ‘vicious circle’ of chronic pain” | groups of 8-10 pts | 4 weeks, meeting 3× per week for 2 hours; followed by less-structured consultations for 8 weeks | Treatment as usual (GP refers pt to PT, chiropractor, etc)
Suman 2009 ^20^ | Educational sessions to provide medical information about FM conducted by medical experts in rheumatology, sports medicine, and pain treatment; aerobic training conducted by sports medicine doctors with “many years of experience in exercise physiology” | CBT aimed at decreasing distorted pain attributions and increasing self-efficacy expectations; relaxation training | combined aerobic and flexibility training; individualized aerobic training with blood-lactate tests to determine intensity and heart rate monitoring; graded increase in duration; stretching regimes | weekly education sessions (see medical component) | | 3 weeks, 5 days per week, 7 hours per day
Suoyrjo 2008 ^215^ | team included physician and nurse | team included psychologist and social worker | team included physiotherapist | goal to instruct pts in physical activities, enhance self-care abilities, improve pain management | course offered in groups of 8 to 12 participants; rehab guidelines as detailed by the Social Insurance Institution; noted to be less strenuous than Mayer/Gatchel | 2 or 3 inpatient periods over the course of a year, totaling 15-18 days
Tollison 1985 ^216^ | full-time staffing includes physical medicine and rehab and rehab nursing; medications managed/reduced | relaxation therapy daily, daily individual and group psychotherapy | 3 daily classes of physical reconditioning, walking, standing, bicycle riding, ROM, physical endurance | daily didactic lectures and discussions led by psychologists, nurses, PTs, and vocational counselors to explain the continuing mechanism of chronic pain, the value of proper body mechanics, etc.; discussions of problems dealing with sexuality and physical disability; how secondary gains can be associated with chronic benign pain | operant conditioning | 3-4 weeks, average 25 days)
Tollison 1989 ^217^ | nerve block evaluation and physical medicine modalities, medication treatment | relaxation training, behavior modification, individual and group psychotherapy | PT, physical strengthening, stamina, and endurance | instruction in body mechanics, variety of educational classes | | approximately 18 days
Tollison 1990 ^218^ | nerve block evaluation and physical medicine modalities, medication treatment | relaxation training, behavior modification, individual and group psychotherapy | PT, physical strengthening, stamina, and endurance | instruction in body mechanics, variety of educational classes | | approximately 18 days
Trief 1995 ^219^ | medical director is an orthopedic surgeon/spine specialist; all pts evaluated at referral; “if appropriate” pts are placed on a medication withdrawal program monitored by staff nurse | training in relaxation using biofeedback; group and individual psychological counseling and individual vocational counseling | PT program of individualized exercise to promote flexibility, strength and aerobic fitness | OT program of education in back protection and body mechanics | | 4-6 weeks, 5 days per week, 6-7 hrs per day
Turk 1998 ^12^ | Pretreatment assessment; 3 1-hr group sessions conducted by a physician trained in pain medicine; 1 brief individual session to monitor medication and address concerns | six 1-hr group sessions conducted by psychologist, designed to be interactive, based on the cognitive-behavioral model; included relaxation, cognitive restructuring, problem solving skill training | four 1-hr group sessions with physical therapist to help pts understand associations among conditioning, aerobic capacity, endurance, and fatigue; 6 1-hr exercise sessions including aerobic and stretching exercises; 6 1-hr OT educational sessions (group) including body mechanics, energy conservation, and pacing | included with all three other components--educational/didactic sessions | group treatment, group size 4 to 7 | 6 half-day sessions spaced over 4 weeks (3 sessions in week one, 1 session per week for remaining 3 weeks)
Turner-Stokes 2003 ^76^ | program staff includes medical staff, all pts received initial clinical assessment; physician provided 10 hrs of direct patient contact plus 8 hours of meetings/documentation | program staff includes psychologist, who provided 24 hrs of direct patient contact plus 8 hours of meetings/documentation; program was CBT based, included relaxation and use of cognitive coping strategies | program staff includes a PT and an OT who each provided 8 hrs of direct patient contact plus 8 hours of meetings/documentation; pts were encouraged to exercise and pace their daily activities at home | included with other components | groups of 8-10 people | 1 afternoon per week for 8 weeks | Same information as group program, but delivered by a psychologist individually; pts had an assessment by a PT before treatment, which informed the recommendations about physical activity and exercises--recommendations were then delivered by the psychologist
van Wilgen 2009 ^220^ | Clinical phase run by a team including a physician; education on bio-psychosocial explanation for pain to replace the bio-medical explanation pts may have had; counseling from a physician 2 hrs per week; medication reduction: all analgesics and pain-related drugs reduced from first day of admission, with aim of no medication within 2 weeks | team running clinical phase includes a psychologist, clinical phase is a cognitive-behavioral model, including 4 hrs per week of psychological treatment, operant treatment, reconceptualization, desensitization, time-management, pacing and self-efficacy, relaxation techniques | physiotherapy 5 hrs per week, exercises, stretching, and PT through a graded activity program, cycling, walking, swimming | included with other components, especially the reconceptualization phase, which began in the pre-clinical phase and involved dealing with “unrealistic thoughts about bodily sensations, the use of medications, altered self-image, lack of control of movements and/or the performance of physical exercises” | participation of a close family member or friend “if necessary”; at discharge, all pts had to have a family member or friend at the evaluation meeting | inpatient clinical phase lasted 3 to 6 weeks | waitlist time for the patients (i.e., not a different population)
Vendrig 1999 ^221^ | Orthopedic surgeon or neurologist on team; all team members provided group sessions; clinical assessment before treatment | group sessions included discussion/training to identify and modify maladaptive behaviors, enhance adequate coping skills, and improve emotional awareness | graded activity to eliminate inappropriate pain behaviors and restore muscle strength, endurance, and aerobic fitness; sports including squash and swimming | group sessions, back school, stress management | Group participation (group size ∼6); stated to be based on Mayer and Fordyce | 4 week duration
Vendrig 2000 ^222^ | Orthopedic surgeon or neurologist on team; all team members provided group sessions | 12 group sessions with clinical psychologist to identify and modify maladaptive behaviors, enhance adequate coping skills, and improve emotional awareness | graded activity to eliminate inadequate pain behaviors and restore muscle strength, endurance, and aerobic fitness | group sessions, back school, stress management | Group participation (group size ∼6); stated to be based on Mayer and Fordyce | 4 week duration
Vendrig 2000 ^223^ | assessment by orthopedic surgeon or neurologist before treatment | PT is based on operant learning principles to abolish inappropriate pain behavior; group sessions addressing pts' beliefs regarding symptoms and disabilities | graded activity program; sports, swimming, squash | education on pain behavior, symptoms and disabilities | | 4 weeks, daily
Verra 2009 ^22^ | regular medical consultations (1 hour/week) including drug therapy | individual psychotherapy including cognitive behavioral therapy; participation in a behavioral therapeutically oriented pain coping/management group, creative activities, relaxation therapy | 5-6 daily sessions of individual, active PT (average 5 hours per week); aerobic endurance training | 3 hours per week of education about pathophysiology and management of chronic disabling pain | traditional Chinese medicine, mainly Qigong (3 hours per week) | 4-weeks
Vines 1996 ^224^ | core disciplines include nursing and physiatry | rehab nurses and social work team teach pts about effective communication, problem solving, conflict resolution, stress management, and relaxation techniques for pain control | pool therapy, stretching, strengthening exercises | nutrition classes, education on proper body mechanics | | 4 weeks, 40 hours per week
Vines 2000 ^225^ | core disciplines include nursing and physiatry | rehab nurses and social work team teach pts about effective communication, problem solving, conflict resolution, stress management, and relaxation techniques for pain control | pool therapy, stretching, strengthening exercises | nutrition classes, education on proper body mechanics | | 4 weeks, 40 hours per week
Vollenbroek-Hutten 2004 ^226^ | supervised by a specialist in physical and rehabilitation medicine | education aimed at reducing fear of movement and learning skills to make optimal use of the remaining physical capabilities | 3 hours conditional training and sport, 0.5 hrs of swimming, 1.5 hrs of OT, and 4 hrs of PT each week for 7 weeks | see behavioral | “if necessary” treatment included psychologist and dietician | 8 weeks, including 7 weeks of group treatment, 9 hours per week | usual care outside the treatment center; allowed to enter programme after 6-mo f/u period
Vowles 2004 ^227^ | similar to Mayer/Gatchel; seen by rehab physician at least once per week | 3 hrs per day of psychoeducational groups, daily contact with psychology | 3 hrs per day of PT and OT; daily contact with PT and OT staff members | part of behavioral; program sought to educate pts about the chronic pain process | | 4-6 weeks long, 6 hrs per day, 5 days per week
Vowles 2007 ^228^ | treatment team includes nurse, physicians | treatment based on Acceptance and Commitment Therapy; daily psychology and relaxation sessions; no direct cognitive restructuring exercises | graded exposure and activation of the whole body in group sessions twice daily | daily health/medical education | group delivered | 3 or 4 weeks
Vowles 2008 ^229^ | treatment team includes nurse, physicians | treatment based on Acceptance and Commitment Therapy; daily psychology and relaxation sessions; mindfulness training, values clarification; no direct cognitive restructuring exercises | graded exposure and activation of the whole body in group sessions twice daily | daily health/medical education | group delivered | 3 or 4 weeks
Vowles 2010 ^230^ | treatment team includes nurse, physicians | treatment based on Acceptance and Commitment Therapy; daily psychology and relaxation sessions; mindfulness training, values clarification; no direct cognitive restructuring exercises | graded exposure and activation of the whole body in group sessions twice daily | daily health/medical education | group delivered | 3 or 4 weeks
Walsh 2002 ^231^ | facilitators included pain nurse specialist, sessional input from a pharmacist and a rheumatologist; education on pain, anatomy, and biomechanics | facilitators included a clinical psychologist; techniques for goal setting, stress management, relaxation and imagery, challenging negative thoughts, communication skills | facilitators included a PT and an OT; treatment included group exercise sessions | workshop sessions on anatomy, medication usage, etc. | group based (7 to 13 per session, median 11); based on Skinner et al., 1990 and Williams et al., 1996 | 9 days spread over 5 weeks, 7 hours per day; plus half-day review sessions 3 mos after completion
Walsh 2004 ^232^ | facilitators included a pain nurse specialist; all pts assessed by multidisciplinary team including pain physician and a spinal surgeon | facilitators included a clinical psychologist; techniques for goal setting, stress management, relaxation and imagery, challenging negative thoughts, communication skills | group exercise sessions | workshop sessions on anatomy, medication usage, etc. | group based (7 to 13 per session, median 11); based on Skinner et al 1990 | 9 days spread over 5 weeks, 7 hours per day; plus half-day review sessions 3 and 9 months after completion
Wang 2008 ^47^ | initial evaluation including clinical exam, radiographic exam, and MRI of the cervical or lumbar spine; some education sessions delivered by orthopedic surgeon; daily sessions with physician | improve skills for individual coping and emotional control; psychotherapy, behavioural therapy, both individual and group sessions; daily sessions with psychologist | physical exercises, ergonomic training, education in back-protection techniques and protective behaviour; goal to increase the pts' activity levels at home and day-to-day functioning to facilitate a return to the workplace | included with physical and behavioral | | 3 weeks, 8-hrs per day, 5 days per week
Wasan 2004 ^233^ | pharmacological treatment including optimization of pain meds, reduction in opioids if appropriate, and prescription of psych meds | cognitive-behavioral therapy focused on coping skills, pacing, and the maladaptive effects of cognitive distortions on pain perceptions; family therapy | PT addressing disuse syndromes: working on flexibility, strength, and aerobic conditioning; OT to improve performance of activities of daily living through careful planning and appropriate pacing, helping patients find meaningful functional goals | focus of program is “to teach patients skills for maintaining their activity levels and mood, despite persistent pain” | half of patients received ECT, based on attending psychiatrist's assessment of severity of depression symptoms and history of previous treatments | non-ECT cases averaged 20.6 days inpatient treatment; ECT cases averaged 40.4 days (due to ECT treatments--average of 10 per patient, range 3 to 20)
Williams 1993 ^234^ | Treatment team includes anesthetist and a nurse; reduction of medication intake; initial clinical exam; see education component as well | “all programme staff applied behavioural principles to all relevant areas of patient activity and inactivity”; treatment team includes 2 psychologists; simple relaxation techniques taught; distraction and other cognitive techniques taught and practiced daily; standard cognitive approaches to fear and depression were taught | Exercise and therapeutic stretch routines with performance goals; manageable timed limits established for sitting, standing, walking were established with pacing and gradual and steady increases in time spent on each activity; program staff included PT and OT | included with behavioural portion; information provided on causes and treatment of pain, rationale of program, effects of activity and inactivity on the body, effects of medication, sleep management, and techniques for establishing new habits of thought and behaviour; pts taught in group sessions and given written backup; all treatment staff contributed to education portion | offered in cohorts of 5 | four weeks, returning home on weekends; program ran 5 days per week, 08:30 to 17:00; outside this time, pts applied methods to their daily routines and activities without direct staff supervision
Williams 1999 ^49^ | Treatment team includes anesthetist and a nurse; reduction of medication intake; initial clinical exam; see education component as well | “all programme staff applied behavioural principles to all relevant areas of patient activity and inactivity”; treatment team includes 2 psychologists; simple relaxation techniques taught; distraction and other cognitive techniques taught and practiced daily; standard cognitive approaches to fear and depression were taught | Exercise and therapeutic stretch routines with performance goals; manageable timed limits established for sitting, standing, walking were established with pacing and gradual and steady increases in time spent on each activity; program staff included PT and OT | included with behavioural portion; information provided on causes and treatment of pain, rationale of program, effects of activity and inactivity on the body, effects of medication, sleep management, and techniques for establishing new habits of thought and behaviour; pts taught in group sessions and given written backup; all treatment staff contributed to education portion | offered in cohorts of 5 | Inpatient program: four weeks, returning home on weekends; program ran 5 days per week, 08:30 to 17:00; outside this time, pts applied methods to their daily routines and activities without direct staff s Outpatient program: eight weeks in single sessions of 3.5 hrs, otherwise, same content | Wait-list for treatment
Wong 2009 ^235^ | Treatment team includes anesthetist who delivers content on medication usage and takes part in the introductory session | Treatment team includes clinical psychologist who delivers content on rationale for self-management, relaxation skills, distraction, thoughts and feelings, sleep management, coping with flareups, planning for the future, and family involvement | Treatment team includes physical therapist who delivers content on pain mechanisms, building up tolerance to activities, exercise theory, and leads group exercise; team also includes OT, who delivers content on the activity diary, targeting and pacing, ADLs | included in all other components | 3 follow-up group meetings at 6-weeks, 18 weeks, and 44 weeks post-training, when psych and physical assessments are completed and content delivered on assertiveness training and topics chosen by patients | eight weeks, with one half-day meeting per week; almost entirely group-delivered
Wormgoor 2008 ^236^ | comprehensive clinical assessment in physical medicine department | cognitive-behavioral approach with training, educational program, and individual counseling | physical training based on sports medicine approach gradually increasing intensity | educational program addressing difference between hurt and harm, etc.; included with co-gbehav | | 3 weeks inpatient
Wright 1999 ^237^ | no info provided--referred to prior PRIDE studies for details | no info provided--referred to prior PRIDE studies for details | no info provided--referred to prior PRIDE studies for details | no info provided--referred to prior PRIDE studies for details | no info provided--referred to prior PRIDE studies for details | no info provided-referred to prior PRIDE studies for details
Zunin 2009 ^238^ | pre-treatment screening including clinical assessment by medical director; re-evaluation at least every 2 weeks by medical director, including medication review | group psychotherapy, breathing exercises, meditation, visualisation | therapeutic movement including “elements of physical therapy,” Feldenkrais, therapeutic yoga | education on pain, pharmacology of pain medicine, lifestyle, diet, risks and benefits of herbs and supplements | therapy provided in groups; program also included introduction to Ho'oponopono led by indigenous Hawaiian practitioner (practice focused on bringing relationships into equilibrium), acupuncture, meditation | 12 weeks, three sessions per week, each 3 hours long

Table D-3 Outcomes

Citation | Patient Characteristics Tested | Outcome Domain | Outcome | Outcome Measure | Outcome Timing
Altmaier 1992 ^92^ | none published | Pain | Self-reported pain | McGill Pain Questionnaire (MPQ): Present Pain Intensity and Pain Rating Index | before treatment, after treatment, 6-month follow-up
| | Physical Functioning | Disability | Low Back Pain Rating Scale | before treatment, after treatment, 6-month follow-up
| | | Self-reported pain | West Haven-Yale Multidimensional Pain Inventory (WHYMPI): Interference and Negative Mood | before treatment, after treatment, 6-month follow-up
| | Role functioning | return to employment | conservative measure: fully employed at same or equivalent job; liberal measure: return to work part-time, working full-time or part-time at same job or lower level, or actively training for a different job | before treatment, after treatment, 6-month follow-up
Jensen 1992 ^158^ | BDI at admission, number of pain areas, duration of pain, MPQ Pain Rating Index, presence of low back pain | Emotional Functioning \| Physical Functioning | Dysfunction among chronic pain patients | Sickness Impact Profile (SIP) | Screening, admission, 3-mo post-treatment
Rainville 1992 ^203^ | sex | Pain | Pain | Pain analog | initial evaluation, program completion
| | | | pain drawing | initial evaluation, program completion
| | | | various: pain with flexion, pain with extension, straight leg raising pain, pain with lifting, pain with bicycle, pain with upper body ergometer | initial evaluation, program completion
| | Physical Functioning | physical performance | various: flexion, extension, straight leg raising degrees, lbs lifted, bicycle minutes, upper body ergometer minutes | initial evaluation, program completion
Davis 1992 ^117^ | none reported | Physical Functioning | Aerobic fitness | 10 exercise indices including VO2 max, METS, WATTS, heart rate, ventilation, etc. | pre- and post-treatment
France 1991 ^132^ | CSF beta-endorphin concentration pre-and post-treatment | Pain | pain change | percentage of pain relief | 1 month post treatment
Connally 1991 ^114^ | pain intensity, duration, number of surgeries, compensation, med usage, activity level, impairment rating, overt pain behavior after lumbar blocks | Clinician or surrogate ratings of global improvement | independent impairment rating | AMA criteria for quantification of impairment | post-treatment
| | Pain | pain intensity | VAS | pre- and post-treatment
| | Pharmacoeconomic/healthcare use | Medication Quantification Scale | MQS | pre- and post-treatment
| | Physical Functioning | Self-reported uptime | daily hours spent out of bed | pre- and post-treatment
Hazard 1991 ^148^ | demographics, physical capacity at initial evaluation, pain intensity, disability exaggeration (modeled using self-assessment of pain and disability compared to physical capacity, in relation to peers) | Emotional Functioning | Self-assessments of pain, disability, depression | BDI | admission, discharge, 1-yr f/u
| | Pain | Self-assessments of pain, disability, depression | MVAS | admission, discharge, 1-yr f/u
| | Participant disposition | Program completion | binary | N/A
| | Physical Functioning | Self-assessments of pain, disability, depression | Oswestry | admission, discharge, 1-yr f/u
| | Role functioning | Work status | binary | 1 yr post treatment, 2 yrs post treatment
Mohler 1991 ^191^ | pain duration | Clinician or surrogate ratings of global improvement | ratings on 9 “problem areas”: medication intake, knowledge of condition, body mechanics, activities of Daily Living, physical condition, functional limitations, employability, psychological adjustment, reported pain | measures rated by treating therapists from the different disciplines | pre-treatment, discharge, follow-up (5 to 17 weeks later, mean 8 weeks)
Deardorff 1991 ^73^ | treated vs. not treated | Pain | subjective pain ratings and interference with daily functioning | self-report on scale of 0 to 100 | evaluation, follow-up
| | Pharmacoeconomic/healthcare use | Medication use | number of potentially addicting medications used | evaluation and f/u
| | Physical Functioning | physical functioning | body mechanics evaluation and number of repetitions performed of various exercises | evaluation and discharge, treated group only
| | Role functioning | employment or vocational rehab status | employed at original position or alternative position, vocational rehab or interviewing, unable to work due to pain | (blank)
Tollison 1990 ^218^ | Compensated vs. uncompensated (i.e., worker's comp) | Pain | Subjective pain intensity | daily 5-pt scale | pre-treatment, discharge, follow-up (3 months)
| | Pharmacoeconomic/healthcare use | Healthcare utilization | additional visits to physicians or hospitalization for pain | pretreatment, discharge, follow-up (3 months)
| | | medication intake | number of pain medications used | pre-treatment, discharge, follow-up (3 months)
| | Physical Functioning | Physical activity | objective physical recordings of strength, stamina, and overall functional activity | pre-treatment, discharge, follow-up (3 months)
| | Role functioning | Return to productivity | full-time employment or school/vocational training | follow-up (3 months)
Kohles 1990 ^168^ | earlier or later cohort; sex | Physical Functioning | Range of motion and strength measures | multiple | admission and discharge
Chapman 1990 ^110^ | consistent vs. inconsistent patients | Clinician or surrogate ratings of global improvement | Pain dramatization | rating by physician | beginning and end of treatment
| | Pain | pain intensity | VAS | beginning and end of treatment
| | Physical Functioning | Activity | Activity diary | beginning and end of treatment
Snow 1990 ^210^ | n/a | Role functioning | vocational status | (blank) | not stated
Cott 1990 ^115^ | with and without field consultant; initial status (working vs. not) | Role functioning | return to work | return to regular work; reduced work disability; job change/retrain; retired, not disabled; remained disabled | 3 mos post-treatment
Skinner 1990 ^207^ | none reported | Emotional Functioning | Distress | VAS | assessment; pretreatment (4 weeks after assessment); end of treatment; 4-wk f/u
| | | Sensory, affective, and behavioural aspects of pain | PLOC | assessment; pretreatment (4 weeks after assessment); end of treatment; 4-wk f/u
| | | | PRQ | assessment; pretreatment (4 weeks after assessment); end of treatment; 4-wk f/u
| | | | Speilberger ‘State’ Anxiety Scale | assessment; pretreatment (4 weeks after assessment); end of treatment; 4-wk f/u
| | | | Zung Self Rating Depression Scale | assessment; pretreatment (4 weeks after assessment); end of treatment; 4-wk f/u
| | Pain | pain intensity | VAS | assessment; pretreatment (4 weeks after assessment); end of treatment; 4-wk f/u
| | | Sensory, affective, and behavioural aspects of pain | MPQ | assessment; pretreatment (4 weeks after assessment); end of treatment; 4-wk f/u
| | Pharmacoeconomic/healthcare use | Medication use | Number of analgesic tablets taken per week | assessment; pretreatment (4 weeks after assessment); end of treatment; 4-wk f/u
| | Physical Functioning | Sensory, affective, and behavioural aspects of pain | ODI | assessment; pretreatment (4 weeks after assessment); end of treatment; 4-wk f/u
Maruta 1990 ^179^ | outcome at dismissal compared to outcome at follow-up | Clinician or surrogate ratings of global improvement | improvement in physical function | 5 categories based on pt behavior and activity; assessment at dismissal ranged from worst (“no change”) to best (“had maximally indicated physical function; was performing most routine work-equivalent activities; initiated physical activities; needed no supervision”); assessment at f/u ranged from worst (“marked decrease in work status”) to best (“marked increase in work status or no change in work status if working full-time before entering pain management | dismissal, 3-yr f/u
| | | modification of attitude | 5 categories based on pt behavior and beliefs: assessment at dismissal ranged from worst (“rejection of program by leaving prematurely”) to best (“fully accepted need to live with pain; had concrete plans to follow through; was able to self-reinforce good behavior and enjoy being active; relatives participated fully in program”); assessment at f/u ranged from worst (“operation [surgery] for the chronic pain problem”) to best (“no further treatment for chronic pain”) | dismissal, 3-yr f/u
| | Pharmacoeconomic/healthcare use | reduction in medication | 5 categories based on pt behavior and medication use; assessment at dismissal ranged from worst (“unsuccessful; resisted medication reduction and left program”) to best (“was off medication; was strongly motivated to stay off maintenance medication and verbalized problems with drug use; appreciated drug-free status”); assessment at f/u ranged from worst (“addicted to pain medication”) to best (“off all pain medication”) | dismissal, 3-yr f/u
Stans 1989 ^212^ | none reported | Coping | Coping Strategies | open-ended questionnaire looking at cognitive and behavioral coping strategies | pre-treatment, post-treatment, 6-mo f/u
| | Emotional Functioning | Anxiety and depression | STAI-Trait anxiety | pre-treatment, 6-mo f/u
| | | | Zung rating-scale | pre-treatment, 6-mo f/u
| | Pain | pain intensity | average pain severity on 6-pt scale | pre-treatment, post-treatment, 6-mo f/u
| | Pharmacoeconomic/healthcare use | analgesic medication use | self-reported frequency of medication intake | pre-treatment, post-treatment, 6-mo f/u
| | Physical Functioning | activity level | up-time, down-time, activities | pre-treatment, post-treatment, 6-mo f/u
Tollison 1989 ^217^ | acute vs. chronic pain | Pain | Subjective pain intensity | daily 5-pt scale | pre-treatment, discharge, follow-up (3 months)
| | Pharmacoeconomic/healthcare use | Healthcare utilization | additional visits to physicians or hospitalization for pain | pre-treatment, discharge, follow-up (3 months)
| | | medication intake | number of pain medications used | pre-treatment, discharge, follow-up (3 months)
| | Physical Functioning | Physical activity | objective physical recordings of strength, stamina, and overall functional activity | pre-treatment, discharge, follow-up (3 months)
| | Role functioning | Return to productivity | full-time employment or school/vocational training | follow-up (3 months)
Hazard 1989 ^147^ | Depression, pain, disability, sex, working/not working | Emotional Functioning | Self-assessments of pain, disability, depression | BDI | initial eval, discharge, 6-12 week f/u, year-end f/u for completers; initial only for comparison and dropouts
| | Pain | Self-assessments of pain, disability, depression | MVAS | initial eval, discharge, 6-12 week f/u, year-end f/u for completers; initial only for comparison and dropouts
| | Physical Functioning | Physical capacity | Quantitative Functional evaluations including flexibility, lifting, flexion, extension, endurance | initial eval, discharge, 6-12 week f/u, year-end f/u for completers; initial only for comparison and dropouts
| | | Self-assessments of pain, disability, depression | Oswestry | initial eval, discharge, 6-12 week f/u, year-end f/u for completers; initial only for comparison and dropouts
| | Role functioning | return to work | telephone interview, in-person interview, or mail questionnaire (all 90 subjects were reached) | 1 yr (6 months for the crossover pts)
Polatin 1989 ^198^ | many pre-treatment variables--psychological, demographic, surgery history, physical flexibility/strength, medications, diagnosis, compensation, time missed work, job type | Participant disposition | treatment completion | completion, drop out, failed to enter | (blank)
| | Role functioning | treatment success | working 1 year post treatment | 1 year
Cassisi 1989 ^109^ | Participants vs. control groups | Pain | Pain | MPQ | initial assessment, average 22-23 months after initial assessment
| | Participant ratings of global improvement and satisfaction with treatment | For treatment completers, satisfaction with/attitudes toward treatment | interview | average 22-23 months after initial assessment
| | Pharmacoeconomic/healthcare use | medical treatments | interview/self-report | initial assessment, average 22-23 months after initial assessment
| | Physical Functioning | Disability | Owestry low back pain disability questionnaire | initial assessment, average 22-23 months after initial assessment
| | Physical functioning \| Role functioning | Global level of functioning | rating system developed by Prolo et al. | initial assessment, average 22-23 months after initial assessment
| | Role functioning | Employment status | rating system developed by Prolo et al. | initial assessment, average 22-23 months after initial assessment
Snow 1988 ^209^ | pts who completed both inpatient and outpatient vs. pts who completed inpatient only | Multiple | self-reported pain-related behaviors | use of medication, health care use, decrease in pain, coping with pain, sleep, time spent in bed, walking ability, loneliness, social activities, family relationship quality | preadmission, follow-up (average 2 yrs post treatment, range 10 to 39 months)
| | Role functioning | Work status | paid employment, work training, retirement with active pursuit of outside hobbies, or functioning actively as a homemaker | preadmission, follow-up (average 2 yrs post treatment, range 10 to 39 months)
Tollison 1985 ^216^ | none reported | Pain | Subjective pain intensity | daily 5-pt scale | pre-treatment, discharge, follow-up (12 months)
| | Pharmacoeconomic/healthcare use | Healthcare utilization | additional visits to physicians or hospitalization for pain | pre-treatment, discharge, follow-up (12 months)
| | | medication intake | number of pain medications used | pre-treatment, discharge, follow-up (12 months)
| | Physical Functioning | Physical activity | objective physical recordings of strength, stamina, and overall functional activity | pre-treatment, discharge, follow-up (12 months)
| | Role functioning | Return to productivity | full-time employment or school/vocational training | pre-treatment, discharge, follow-up (12 months)
Gatchel 1986 ^137^ | sex | Emotional Functioning | psychological functioning | MMPI | intake, 6-mo f/u
| | | Self-report psychological assessment created for persons being treated/ assessed in medical settings for physical disorders | Millon Behavioral Health Inventory (MBHI) | intake, discharge, 3-mo, 6-mo f/u
| | | self-reported pain/disability | BDI | intake, discharge, 3-mo, 6-mo f/u
| | Pain | self-reported pain/disability | analogue rating | intake, discharge, 3-mo, 6-mo f/u
| | | | pain drawing | intake, discharge, 3-mo, 6-mo f/u
| | Physical Functioning | Physical Function | numerous quantified physical measures of strength, extension, flexion | Admission, discharge, 3-mo f/u
Mayer 1986 ^183^ | change in trunk strength; ROM scores | Emotional Functioning | Psychological testing | BDI | admission, 3 mos post-treatment for PRIDE group
| | | | Million Analog | admission, 3 mos post-treatment for PRIDE group
| | | | pain drawing | admission, 3 mos post-treatment for PRIDE group
| | Litigation and claims | resolution of workers compensation litigation | % | avg 5 mos post-treatment for PRIDE group
| | Pharmacoeconomic/healthcare use | additional back surgery | % | avg 5 mos post-treatment for PRIDE group; approx. 11-15 mos for comparison
| | | additional medical care | number of hospitalizations, studies, visits to other physicians | avg 5 mos post-treatment for PRIDE group
| | Physical Functioning | Functional capacity | variety of physical exams (strength, flexion/extension) | admission, 3 mos post-treatment for PRIDE group
| | Role functioning | return to work | full-time work, full-time training, inactive | avg 5 mos post-treatment for PRIDE group; approx. 11-15 mos for comparison
Gatchel 1986 ^136^ | sex, MBHI scales | Emotional Functioning | psychological functioning | MMPI | intake, 6-mo f/u
| | | Self-report psychological assessment created for persons being treated/ assessed in medical settings for physical disorders | Millon Behavioral Health Inventory (MBHI) | intake, discharge, 3-mo, 6-mo f/u
| | | self-reported pain/disability | BDI | intake, discharge, 3-mo, 6-mo f/u
| | Pain | self-reported pain/disability | analogue rating | intake, discharge, 3-mo, 6-mo f/u
| | | | pain drawing | intake, discharge, 3-mo, 6-mo f/u
| | Physical Functioning | Physical Function | numerous quantified physical measures of strength, extension, flexion | Admission, discharge, 3-mo f/u
Mayer 1987 ^184^ | sex | Emotional Functioning | self-report psychological measures | BDI | admission, 3 mos post-treatment for treatment completers
| | | | Million Analog | admission, 3 mos post-treatment for treatment completers
| | Pain | self-report psychological measures | pain drawing | admission, 3 mos post-treatment for treatment completers
| | Pharmacoeconomic/healthcare use | additional back surgery | % of pts having | 1-yr f/u, 2-yr f/u
| | | visits to health care professionals | % pts visiting new professionals for same injury/pain; number of visits | 1-yr f/u, 2-yr f/u
| | Physical Functioning | Functional capacity | variety of physical exams (strength, flexion/extension) | admission, 3 mos post-treatment for treatment completers
| | Role functioning | return to work | working or in a training program | 1-yr f/u, 2-yr f/u
Kleinke 1988 ^167^ | preference for treatment modalities | Clinician or surrogate ratings of global improvement | Behavioral ratings by Primary Nurse | Activity (4 pt scale from none to exerts leadership [in being active]), pain behavior (4 pt scale from none to almost constant) | first and last weeks of program
| | Emotional Functioning | Depression | BDI | first and last weeks of program
| | | mood | Profile of Mood States (POMS) | first and last weeks of program
| | | Pain behaviors: grimacing, guarded movement, bracing, position shifts, partial movement, limitation statements, sounds | Audiovisual Taxonomy: videotaped sessions of performing activities (walking, picking up an object, etc) which are rated for percentage of intervals during which pain behaviors occur | first and last weeks of program
| | | Self-handicapping | pt self-rating of how their physical performance on AV Taxonomy items would be hindered by pain problem | first and last weeks of program
| | Pain | Pain | MPQ | first and last weeks of program
Mayer 1988 ^185^ | sex | Physical Functioning | Functional capacity | variety of physical exams (strength, flexion/extension) | admission, discharge
Guck 1988 ^145^ | MMPI subgroups, sex, pretreatment variables/demogr aphics | Emotional Functioning | Depression | BDI | 1 to 5 yrs following treatment
| | Pain | Pain | VAS for a good day, bad day, monthly average, today | 1 to 5 yrs following treatment
| | Pharmacoeconomic/healthcare use | health treatments | number of pain-related hospitalizations, number of pain-related surgeries, use of nonnarcotic, narcotic, and psychotropic medications | 1 to 5 yrs following treatment
| | Physical Functioning | Functional capacity | ability to do work, do yardwork/shop, socialize, recreate, exercise, sleep | 1 to 5 yrs following treatment
| | Role functioning | Socioeconomic | employment status, financial compensation, pending litigation | 1 to 5 yrs following treatment
Middaugh 1988 ^190^ | age (55+ vs. younger than 55) | Emotional Functioning | Psychologic functioning | SCL-90R | evaluation and follow-up (6-12 mos later)
| | Pain | VAS | current, maximum, minimum pain levels | evaluation and follow-up (6-12 mos later)
| | Pharmacoeconomic/healthcare use | health care use | number of visits to doctor, ER, and hospital | evaluation and follow-up (6-12 mos later)
| | | medication intake | MQS | evaluation and follow-up (6-12 mos later)
| | Physical Functioning | length of time pt was able to walk | (blank) | evaluation and follow-up (6-12 mos later)
| | | uptime daily | time spent out of a reclining position | evaluation and follow-up (6-12 mos later)
| | Role functioning | Employment status | hours per week spent in in paid employment, housework, yardwork, childcare, volunteer work, or school | evaluation and follow-up (6-12 mos later)
Moore 1986 ^24^ | MMPI subgroups | Emotional Functioning | Moods: tension, depression, anger, vigor, fatigue, confusion | Profile of Mood States (POMS) | before and after treatment; also 2-5 mos before treatment for the 32 pts who were initially waitlisted
| | | Personality characteristics | MMPI | before and after treatment; also 2-5 mos before treatment for the 32 pts who were initially waitlisted
| | | | Rathus Assertiveness Schedule (RAS) | before and after treatment; also 2-5 mos before treatment for the 32 pts who were initially waitlisted
| | | | Tennessee Self-Concept Scales (TSCS) | before and after treatment; also 2-5 mos before treatment for the 32 pts who were initially waitlisted
| | Interpersonal Functioning | Sexual functioning | monthly frequency; % normal desire; % normal ability | before and after treatment; also 2-5 mos before treatment for the 32 pts who were initially waitlisted
| | Pain | Pain severity | Pain Appraisal Inventory | before and after treatment; also 2-5 mos before treatment for the 32 pts who were initially waitlisted
| | Physical Functioning | Activity diaries | Kept by pts and monitored by nursing staff; time spent standing/walking, sitting, reclining, and sleeping | duration of treatment
| | | sleep dysfunction | (blank) | before and after treatment; also 2-5 mos before treatment for the 32 pts who were initially waitlisted
Doleys 1986 ^120^ | Pre-treatment narcotics usage | Pain | Hourly subjective pain ratings | 24-hour daily sheet as described by Fordyce | evaluation period, pre-treatment, post-treatment
Bendix 1995 ^81^ | treatment group | Pain | pain: back and leg | scale 0 to 10 | 4-mo f/u
| | Pharmacoeconomic/healthcare use | contacts with health care system | count | before treatment, 4-mo f/u
| | Physical Functioning | function | 15 questions about back problem interference with ADLs (Low back pain rating scale) | 4-mo f/u
| | | physical activity | “are you participating in any kind of physical sports activity?” | 4-mo f/u
| | Role functioning | days of sick leave | count | before treatment, 4-mo f/u
| | | Work readiness | working, studying/training, or looking for work (“As Denmark has a high unemployment rate, nobody is guaranteed a job”) | before treatment, 4-mo f/u
Trief 1995 ^219^ | BDI scores at preprogram | Clinician or surrogate ratings of global improvement | Physical Therapy | % improvement overall, as rated by therapists: 0-20%, 21-40%, 41%+ | discharge
| | | Psychology | Therapist-rated adjustment/progress (3 categories) | discharge
| | | Vocational | Therapist-rated involvement/progress (3 categories--top category is “employed on admission or scheduled to return to work or school”) | discharge
| | Other | Biofeedback | Therapist-rated awareness and control, use of skills (3 categories) | discharge
| | | Occupational Therapy | Therapist-rated knowledge and application of body mechanics principles (3 categories) | discharge
Jensen 1995 ^155^ | deteriorated vs. improved; treatment group | Emotional Functioning | Anxiety | VAS, recorded 3 times per day for 7 days | pre treatment, post treatment, 6-mo f/u
| | | helplessness | Arthritis Helplessness Index (modified for neck/shoulder pain) | pre treatment, post treatment, 6-mo f/u
| | Interpersonal Functioning | marital satisfaction | Index of Marital Satisfaction Scale | pre treatment, post treatment, 6-mo f/u
| | Pain | pain intensity | VAS, 3 times per day for 7 days | pre treatment, post treatment, 6-mo f/u
| | Physical Functioning | Disability | Stanford Health Assessment Questionnaire | pre treatment, post treatment, 6-mo f/u
| | Role functioning | Absenteeism | info on sick leave from national health insurance authority | one-year prior to treatment, 1.5 years after treatment
Chapman 1994 ^111^ | MMPI clusters (seven) | Pain | Subjective pain intensity | VAS | pre-treatment and post-treatment, follow-up (6 to 66 months after end of treatment)
| | Pharmacoeconomic/healthcare use | Medication use | Medication diary; “Use” defined as taking 2 or more tablets per week for each of 6 categories (opiates, barbiturates, tranquilizers, non-narcotic pain meds, antidepressants, and phenothiazines) | pre-treatment and post-treatment, follow-up (6 to 66 months after end of treatment)
| | Physical Functioning | activity level | Activity Diary described by Chapman et al 1981 | pre-treatment and post-treatment, follow-up (6 to 66 months after end of treatment)
| | Role functioning | Current work or school status | self-report | follow-up (6 to 66 months after end of treatment)
Gatchel 1994 ^138^ | Axis I and Axis II psychological disorders | Role functioning | return to work | full-time or part-time employment at 1-yr post-treatment period | 1-yr
Jensen 1994 ^159^ | change in pain beliefs (Survey of Pain Attitudes), change in coping responses/behavi ors (CSQ plus number of days out of past week when 7 further strategies were used), age, pain intensity | Emotional Functioning | psychological functioning | BDI | admission, f/u (3-6 mos)
| | Pharmacoeconomic/healthcare use | Use of medical services | number of pain-related visits made to physicians during prior 3 months | admission, f/u (3-6 mos)
| | Physical Functioning | physical functioning | Physical Dysfunction scale of SIP | admission, f/u (3-6 mos)
Alaranta 1994 ^91^ | sex, age | Emotional Functioning | Pain and Disability Index | Million index | baseline, 12-month follow-up
| | | psychological measures | self-report questionnaires, modified for study, taken from BDI, Symptom Check List, Multidimensional Health Locus of Control, Social Adjustment Scale; Karolinska Scales of Personality | baseline, 3-month, 12-month except Karolinska not assessed at 3-month f/u
| | Pharmacoeconomic/healthcare use | Use of Medical Care Services | number of visits to doctors and outpatient PT periods | baseline and 12-month follow-up
| | Physical Functioning | physical measurements | flexibility of trunk, muscular strength and endurance | baseline, 3-month, 12-month follow-ups
| | | Pt reported physical performance and leisure time physical activities | questionnaire | baseline, 3-month, 12-month follow-up
| | Role functioning | Sick-leave days and occupational handicap | number of sick leave days in previous year (Social Insurance Institution data), WHO occupational Handicap | baseline, 12-month f/u
Jensen 1994 ^156^ | treatment, control, reference group (all pts treated, including those who could not be matched to controls) | Emotional Functioning | Anxiety | VAS, recorded 3 times per day for 7 days | baseline, before treatment, end of treatment, 6-mo f/u
| | | Depression | BDI | baseline, before treatment, end of treatment, 6-mo f/u
| | Pain | pain intensity | VAS, recorded 3 times per day for 7 days | baseline, before treatment, end of treatment, 6-mo f/u
| | Physical Functioning | Disability | Health Assessment Questionnaire | baseline, before treatment, end of treatment, 6-mo f/u
| | Role functioning | absenteeism | leave of absence details from National Health Insurance authority for 1 year before treatment and 6 months after | (blank)
Scharff 1994 ^25^ | 0 | Pain | self-report of headache pain | Headache Index (incorporates headache intensity and frequency) | pre-treatment, follow-up (6-7 mos later)
Mayer 1994 ^180^ | sex, discectomy status (yes/no) | Physical Functioning | Functional capacity | variety of physical exams (strength, flexion/extension) | intake, intensive phase admission, follow-up (varies)
Rainville 1993 ^204^ | completers vs. drop outs | Emotional Functioning | Depression | BDI | pre-treatment, post-treatment (completers only)
| | | Pain and impairment beliefs | Pain and Impairment Relationship Scale (PAIRS) scale scores | pre-treatment, post-treatment (completers only)
| | Pain | Pain | Pain intensity score on VAS | pre-treatment, post-treatment (completers only)
| | | | quantified pain drawing | pre-treatment, post-treatment (completers only)
| | Participant disposition | Completion vs. drop out | binary | N/A
| | Physical Functioning | Disability | MVAS | pre-treatment, post-treatment (completers only)
Williams 1993 ^234^ | none reported | Emotional Functioning | Confidence performing activities despite pain | Pain Self-Efficacy Questionnaire | pre-treatment, post-treatment, 1-mo f/u, 6-mo f/u
| | | Depression | BDI | pre-treatment, post-treatment, 1-mo f/u, 6-mo f/u
| | Other | Use of program coping strategies (exercise, stretch, relaxation) | frequency, self-reported | 1-mo f/u, 6-mo f/u
| | Pharmacoeconomic/healthcare use | Medication use | NSAIDS, opioid analgesics, antidepressants, benzodiazepines, other | pre-treatment, post-treatment, 1-mo f/u, 6-mo f/u
| | Physical Functioning | Impact of pain on day-to-day functioning | SIP (Sickness Impact Profile) | pre-treatment, post-treatment, 1-mo f/u, 6-mo f/u
| | | physical functioning | 10-minue walk | pre-treatment, post-treatment, 1-mo f/u, 6-mo f/u
| | | | sit-ups to tolerance | pre-treatment, post-treatment, 1-mo f/u, 6-mo f/u
| | | | stairs climbed in 2-minutes | pre-treatment, post-treatment, 1-mo f/u, 6-mo f/u
Sanders 1993 ^26^ | Cluster analysis based on Sickness Impact Profile (SIP) and Medical Examination and Diagnostic Information Coding System (MEDICS) | Emotional Functioning | Depression | BDI | pre- and post-treatment (3-6 months later)
| | Pain | pain intensity | VAS | pre- and post-treatment (3-6 months later)
| | Pharmacoeconomic/healthcare use | Medication Quantification Scale | MQS | pre- and post-treatment (3-6 months later)
| | Physical Functioning | Self-reported uptime | daily hours spent out of bed | pre- and post-treatment (3-6 months later)
| | Role functioning | Employment | % working | pre- and post-treatment (3-6 months later)
Lipchik 1993 ^48^ | treatment vs. control | Emotional Functioning | Pain beliefs and perceptions | PBAPI | intake, discharge (or 3-weeks later, for control group)
| | | Pain locus of control | PLOC | intake, discharge (or 3-weeks later, for control group)
| | Pain | Subjective pain intensity | scale 0 to 10 | intake, discharge (or 3-weeks later, for control group)
| | Pharmacoeconomic/healthcare use | Medication usage | all usage recorded: narcotic/non-narcotic analgesics, antidepressants, muscle relaxants, anxiolytics, sedatives/hypnotics, anticonvulsants | intake, discharge (or 3-weeks later, for control group)
Feuerstein 1993 ^129^ | 0 | Role functioning | Vocational Outcome | structured interview by research assistant: employed full time, part time, enrolled in vocational training/retraining, currently unemployed | average 17-18 months
Vines 1996 ^224^ | none reported | Pain | Pain levels | VAS | admission, discharge, follow-up (3-11 mos after completion)
| | Pharmacoeconomic/healthcare use | opioid use | self-report | admission, follow-up (3-11 mos after completion)
| | Physical Functioning | Activity levels and sleep disturbance | days/nights per week experiencing reduced activity/disturbed sleep | admission, discharge, follow-up (3-11 mos after completion)
| | | down time | total hours per day spent resting | admission, follow-up (3-11 mos after completion)
| | Role functioning | role function status | number of hours per week pt was active, whether at job, school, job training, volunteer, household | admission, follow-up (3-11 mos after completion)
Bendix 1996 ^43^ | treatment vs. control | Pain | pain: back and leg | scale 0 to 10 | 4-mo f/u
| | Pharmacoeconomic/healthcare use | contacts with health care system | count | 4-mo f/u
| | Physical Functioning | function | 15 questions about back problem interference with ADLs (Low back pain rating scale) | 4-mo f/u
| | | isometric back-muscle endurance | Biering-Sørenson test | 4-mo f/u
| | Role functioning | Work readiness | working, studying/training, or looking for work (“As Denmark has a high unemployment rate, nobody is guaranteed a job”) | 4-mo f/u
Lynch 1996 ^175^ | pre- and post-treatment, completers vs. non-completers, hopelessness | Coping | Coping Strategies | Coping Strategy Questionnaire (CSQ) | follow-up
| | Emotional Functioning | Depression | BDI | screening, follow-up
| | | Negative expectancies about future, hopelessness, pessimism | Beck Hopelessness Scale (BHS) | screening, follow-up
| | Participant ratings of global improvement and satisfaction with treatment | Activity level, pain status, program satisfaction (if applicable) | Pain Management Program Evaluation Questionnaire (PMPEQ); includes self-report of: employment, exercise activity, flexibility/endurance/strength, pain intensity and type; interference by pain on specific activities; changes in sleep/weight/alcohol consumption | screening, follow-up
Garcy 1996 ^135^ | Demographic, physical, psychologic measures before and after treatment | Physical Functioning | new injury | injury to a different musculoskeletal area | within 1 year of treatment completion
| | Role functioning | lost work time after reinjury | self-reported lost work time due to recurrent or new injury | within 1 year of treatment completion
| | | work retention | not specified | one year post-treatment
| | Symptoms and adverse events | recurrent injury | another injury to the same spinal area | within 1 year of treatment completion
Elkayam 1996 ^126^ | Results of CT scan: normal vs. abnormal CT; with/without spinal stenosis; with/without disc bulging | Clinician or surrogate ratings of global improvement | physician rated outcome | Stauffer and Coventry Criteria of Outcome (includes pain relief, physical activity limitations, use of analgesic medications) | end of treatment
| | Pain | pain intensity and daily duration | VAS | pre-treatment, post-treatment, 6-mo f/u
| | Pharmacoeconomic/healthcare use | medication consumption | no analgesics, NSAIDs, common analgesics, narcotics | pre-treatment, post-treatment, 6-mo f/u
Elkayam 1996 ^125^ | improvement vs. no improvement for marital status, unemployed/employed, pain location, previous surgery, psychological factors, personality traits (including personality disorders, familial problems, dysthmia, anxiety, OCD, good functioning), “secondary gains” as assessed by psychologist average scores on the following scales are reported by outcome category (poor, moderate, good): centrality of back pain in patient's life, extent of expectations from treatment, extent of support | Clinician or surrogate ratings of global improvement | physician rated outcome | Stauffer and Coventry Criteria of Outcome (includes pain relief, physical activity limitations, use of analgesic medications) | end of treatment
| | Pain | pain intensity and daily duration | VAS | pre-treatment, post-treatment, 6-mo f/u
| | Pharmacoeconomic/healthcare use | medication consumption | no analgesics, NSAIDs, common analgesics, narcotics | pre-treatment, post-treatment, 6-mo f/u
Flavell 1996 ^131^ | none reported | Pain \| Emotional Functioning | pain severity, interference, sense of control, negative mood, activity level | WHYMPI | Before treatment, after treatment, 3-mo f/u
| | Physical Functioning | physical functioning | 4-minute walk test | Before treatment, after treatment, 3-mo f/u
Luoto 1996 ^173^ | outcome (good vs. poor) compared to control group; sex | Neuropsychological assessments of cognitive and motor function | postural control | measured with a vertical force platform, looking at change in center of body mass over 15 seconds when patient was standing still | beginning of treatment, 6-mo f/u
| | | psychomotor speed (reaction time) | measured with accuracy of 1/100 of a second; measured on upper and lower limb | beginning of treatment, 6-mo f/u
| | Physical Functioning | Rehab outcome | ODI: restoration considered effective if Oswestry index decreased after treatment | before treatment, 6-mo f/u
Fricton 1996 ^133^ | psychosocial items from IMPATH:TMJ instrument | Pain | self-report severity of pain | Symptom Severity Index (SSI) | pretreatment, 6 month f/u
| | Physical Functioning | Problems in mandibular movement, TMJ noise, muscle and joint tenderness | Craniomandibular Index | pretreatment, 6 month f/u
Chapman 1996 ^112^ | Treatment Helpfulness Questionnaire response correlations | Coping | Coping | Ability to cope with pain and related problems, ranging from 1 to 5 | pre-treatment and follow-up (3-6 mos)
| | Emotional Functioning | Depression | BDI | pre-treatment and post-treatment
| | Pain | Subjective pain intensity | VAS | pre-treatment and post-treatment, follow-up (3-6 months)
| | Pharmacoeconomic/healthcare use | Medication use | MQS | pre-treatment and follow-up (3-6 mos)
Hildebrandt 1997 ^150^ | predictors of back-to-work: application for pension, poor pt. expectation before treatment concerning “back-to-work”, time off from work, job as truck driver; educational status, prior hospitalizations, disability (daily functioning); changes in: disability, depression, individual physical treatment; similar analyses conducted for other outcome variables | Coping | Coping | FEKB (German language) | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Emotional Functioning | Depression | Depressivitäs-Skala | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Pain | pain intensity | VAS | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Pharmacoeconomic/healthcare use | Use of health care system | Physician visits and physical treatments in the 12 months before and after treatment | pre, post
| | Physical Functioning | “psychovegetative reports” | psychovegetative reports scale | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | Disability | FFbH | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | | PDI | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | physical performance | flexion and extension, strength/lifting capacity, endurance, as measured by PT and physician | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Role functioning | Work status | back to work ratio | 12-mo f/u
Bendix 1997 ^79^ | treatment group, drop-outs | Pain | pain: back and leg | scale 0 to 10 | before treatment, 12-mo f/u
| | Pharmacoeconomic/healthcare use | contacts with health care system | count | before treatment, 12-mo f/u
| | Physical Functioning | function | 15 questions about back problem interference with ADLs (Low back pain rating scale) | before treatment, 12-mo f/u
| | | physical activity | “are you participating in any kind of physical sports activity?” | 12-mo f/u
| | Role functioning | days of sick leave | count | before treatment, 12-mo f/u
| | | Work readiness | working, studying/training, or looking for work (“As Denmark has a high unemployment rate, nobody is guaranteed a job”) | before treatment, 12-mo f/u
Polatin 1997 ^199^ | Waddell behavioral signs: increase, decrease, no change | Pharmacoeconomic/healthcare use | health utilization (new provider) | seeing new provider for same issue | 1-yr f/u
| | | new surgery to treated area | % reporting | 1-yr f/u
| | Physical Functioning | Waddell nonorganic signs | (blank) | pre-treatment, post treatment
| | Role functioning | return to work | any work during f/u | 1-yr f/u
| | | work retention | “remained working” at time of f/u | 1-yr f/u
| | Symptoms and adverse events | recurrent injury | % reporting | 1-yr f/u
Andary 1997 ^93^ | 0 | Role functioning | Employment status | full-time competitive, part-time competitive, supported/sheltered work, homemaker and student, homemaker only, unemployed | admission to program, discharge from program, most recent follow-up (0 to 36 months following discharge)
Pfingsten 1997 ^74^ | predictors of back-to-work: application for pension, poor pt. expectation before treatment concerning “back-to-work”, time off from work, change in disability, change in depression | Coping | Coping | FEKB (German language) | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Emotional Functioning | Depression | Depressivitäs-Skala | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Pain | pain intensity | VAS | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Pharmacoeconomic/healthcare use | Use of health care system | Physician visits and physical treatments in the 12 months before and after treatment | pre, post
| | Physical Functioning | Disability | PDI | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | physical performance | flexion and extension, as measured by PT and physician | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Role functioning | Work status | back to work ratio | 12-mo f/u
Mayer 1998 ^75^ | discectomy, fusion, discectomy control, fusion control | Pharmacoeconomic/healthcare use | New surgery | New surgery to same area | 1-yr f/u
| | | Seeking treatment from new provider | % of pts, number of visits | 1-yr f/u
| | Role functioning | work retention | was working within 2-wks of f/u interview | 1-yr f/u
| | | work return | had returned to work anytime during f/u including short-term training | 1-yr f/u
| | Symptoms and adverse events | recurrent injury | injury to same area, with or without lost work time | 1-yr f/u
Bendix 1998 ^97^ | treatment/control group | Pain | pain: back and leg | scale 0 to 10 | 24-mo f/u
| | Pharmacoeconomic/healthcare use | contacts with health care system | count | 24-mo f/u
| | Physical Functioning | function | 15 questions about back problem interference with ADLs (Low back pain rating scale) | 24-mo f/u
| | | physical activity | “are you participating in any kind of physical sports activity?” | 24-mo f/u
| | Role functioning | days of sick leave | count | 24-mo f/u
| | | Work readiness | working, unemployed but actively seeking work/rehabilitation-paid work/education, on long term sick leave, pension application pending, pension obtained | before treatment, 24-mo f/u
Burns 1998 ^104^ | changes in cognitive and physical capacity pre- and post-treatment | Emotional Functioning | Pain Helplessness | Arthritis Helplessness Index adapted by replacing “Arthritis” with “Pain” in questions | 1 week before treatment, at discharge, 3-6 mo f/u
| | Pain | Pain severity | Pain Severity subscale of MPI | pretreatment, post-treatment, 3-6 mo f/u
| | Physical Functioning | Activity levels | MPI | pretreatment, post-treatment, 3-6 mo f/u
| | | hours of downtime | self-reported number of hours of a typical day pts had to lie down or sit because of pain | pre-treatment, 3-6 mo f/u
| | | Lifting capacity | Progressive Isoinertial Lifting Evaluation (PILE) | pre-treatment, post-treatment
| | | Walking endurance | treadmill test | pre-treatment, post-treatment
Bendix 1998 ^95^ | treatment/control group, dropouts | Pain | pain: back and leg | scale 0 to 10 | before treatment, 60-mo f/u
| | Pharmacoeconomic/healthcare use | contacts with health care system | count | 60-mo f/u
| | | prescription medications | scored based on type of meds and frequency of use | 60-mo f/u
| | Physical Functioning | function | 15 questions about back problem interference with ADLs (Low back pain rating scale) | before treatment, 60-mo f/u
| | | physical activity | “are you participating in any kind of physical sports activity?”, days of sport activity per week | before treatment, 60-mo f/u
| | | Quality of Life | 5-pt scale: better or worse in relation to low-back pain | 60-mo f/u
| | Role functioning | days of sick leave | count | 60-mo f/u
| | | Work readiness | working, unemployed but actively seeking work/rehabilitation-paid work/education, on long term sick leave, pension | before treatment, 60-mo f/u
Jensen 1998 ^157^ | treatment vs. control | Coping | pain coping ability | questionnaire | 18-mo f/u
| | Interpersonal Functioning | personal life (relationships, friends, lifestyle, etc.) | questionnaire | 18-mo f/u
| | Pain | pain intensity | VAS, recorded 3 times per day for 7 days | pre-treatment, post-treatment, 6-mo f/u, 18-mo f/u
| | Role functioning | absenteeism | leave of absence details from National Health Insurance authority for 1 year before treatment and 18 months after | (blank)
| | | work situation (changed workplace, changed work task, etc.) | questionnaire | 18-mo f/u
Bendix 1998 ^96^ | many pre-treatment variables, plus treatment groups | Pain | change in leg and back pain severity | severity of pain rated 0 to 10 | before treatment, 12-mo f/u
| | Participant disposition | completion vs. withdrawal from treatment | (blank) | (blank)
| | Participant ratings of global improvement and satisfaction with treatment | Subjective overall assessment of back problems | 5 pt scale: much worse to much better compared to before treatment | 12-mo f/u
| | Physical Functioning | change in level of ADLs | 15 questions about back problem interference with ADLs (Low back pain rating scale)? [not specified] | before treatment, 12-mo f/u
| | Role functioning | ability to work | working or looking for work/education, disability pension status, etc. | 12-mo f/u
Burns 1998 ^103^ | Anger management style as measured by Anger Expression Inventory; gender | Emotional Functioning | Depression | BDI | pre- and post-treatment
| | Pain | Pain severity | Pain Severity subscale of MPI | pre- and post-treatment
| | Physical Functioning | Activity levels | MPI | pre- and post-treatment
| | | Lifting capacity | Progressive Isoinertial Lifting Evaluation (PILE) | pre-treatment, post-treatment
| | | Walking endurance | treadmill test | pre-treatment, post-treatment
Turk 1998 ^12^ | scores on MPI pain, activity, solicitous responses; CES-D, ODI, and whether onset was idiopathic were reported against response vs. non-response to treatment | Emotional Functioning | Depression | CES-D | pretreatment, post-treatment, six-month follow-up
| | Interpersonal Functioning | marital satisfaction | Locke-Wallace Marital Adjustment Scale (LWMAS) | pretreatment, post-treatment
| | Pain \| Emotional Functioning | Pain severity, perceived interference, affective distress, perceived control over life, support form significant others, responses from significant others, performance of a set of common activities | Multidimensional Pain Inventory | pretreatment, post-treatment, six-month follow-up
| | Physical Functioning | Disability | Oswestry Disability Index (ODI) | pretreatment, post-treatment, six-month follow-up
| | | Health status | Fibromyalgia Impact Questionnaire (FIQ) | pretreatment, post-treatment, six-month follow-up
Luoto 1998 ^174^ | outcome (good vs. poor) compared to control group; sex; initial postural stability for severe LBP vs. moderate LBP vs. control | Neuropsychological assessments of cognitive and motor function | externally disturbed postural control | measured with a vertical force platform, looking at change in center of body mass over 15 seconds when patient was standing still; also measured with vibration stimulation of muscles and with eyes open and closed | beginning of treatment, 6-mo f/u
| | Physical Functioning | Rehab outcome | ODI: restoration considered effective if Oswestry index decreased after treatment | before treatment, 6-mo f/u
Guck 1999 ^80^ | PAIRS scores | Emotional Functioning | Changes in pain beliefs | Pain and Impairment Relationship Scale (PAIRS) | beginning of treatment, end of treatment, 6-mo f/u
| | | Depression | BDI | beginning of treatment, 6-mo f/u
| | Pain \| Emotional Functioning | Pain severity, interference, and life control | MPI | beginning of treatment, 6-mo f/u
| | Pharmacoeconomic/healthcare use | health care use | Health care visits per month due to chronic nonmalignant pain after treatment; hospitalizations due to chronic nonmalignant pain after treatment | 6-mo f/u
| | | Medication use | Medication Quantification Scale (MQS) | beginning of treatment, 6-mo f/u
Wright 1999 ^237^ | Cervical Spine vs. Lumbar Spine Disorder | Litigation and claims | Persistent $ dispute | ongoing financial disputes or litigation related to the injury | 1-yr f/u
| | Pharmacoeconomic/healthcare use | New surgery | New surgery to same area | 1-yr f/u
| | | Seeking treatment from new provider | % of pts, number of visits | 1-yr f/u
| | Role functioning | work retention | maintained employment during entire post-treatment period | 1-yr f/u
| | | work return | any return to work | 1-yr f/u
| | Symptoms and adverse events | recurrent injury | injury to same area, with or without lost work time | 1-yr f/u
Vendrig 1999 ^221^ | demographic/socioeconomic data, physical measures, psychological measures | Emotional Functioning | somatic distress and depression | MMPI-2 | pre-treatment, 6-mo f/u
| | Pain | experience of pain | pain drawing | pre-treatment, 6-mo f/u
| | | | VAS | pre-treatment, 6-mo f/u
| | Physical Functioning | Disability | QBPDS | pre-treatment, 6-mo f/u
| | | physical functioning | lumbar extension and flexion, cardiovascular fitness (V02 max) | pre-treatment, 6-mo f/u
| | Role functioning | return to work | complete vs. incomplete | 6-mo f/u
Williams 1999 ^49^ | randomized vs. refused randomization; treatment program by randomized vs. elective; treatment vs. waitlist; inpatient vs. outpatient | Emotional Functioning | Catastrophic thinking | Catastrophizing subscale of CSQ | (blank)
| | | Confidence performing activities despite pain | Pain self-efficacy questionnaire (PSEQ) | pre-treatment, post-treatment, 1-mo f/u, 12-mo f/u
| | | Depression | BDI | pre-treatment, post-treatment, 1-mo f/u, 12-mo f/u
| | Other | Use of program coping strategies (exercise, stretch, relaxation) | frequency, self-reported | 1-mo f/u, 6-mo f/u
| | Pain | pain intensity | 0 to 100 scale (average pain and pain distress over last week) | pre-treatment, post-treatment, 1-mo f/u, 12-mo f/u
| | Pharmacoeconomic/healthcare use | Medication use | NSAIDS, opioid analgesics, antidepressants, benzodiazepines, other | pre-treatment, post-treatment, 1-mo f/u, 12-mo f/u
| | Physical Functioning | Impact of pain on day-to-day functioning | SIP (Sickness Impact Profile) | pre-treatment, post-treatment, 1-mo f/u, 12-mo f/u
| | | physical functioning | 10-minue walk | pre-treatment, post-treatment, 1-mo f/u, 12-mo f/u
Gatchel 1999 ^139^ | Program completion, work retention, SF-36 change | Litigation and claims | claim settlement | settlement of pt's disability-related compensation claim | 1-yr
| | Pharmacoeconomic/healthcare use | new healthcare provider | % of pts seeking healthcare from a new provider, suggesting dissatisfaction with health status and disability determinations by current treating and referring doctors | 1-yr
| | | New surgery | surgery to the original compensable injured area during the post-treatment year | 1-yr
| | | Number of healthcare visits | 0 vs. 1+ visits in year post treatment | 1-yr f/u
| | Physical Functioning | Health status | SF-36 | pre-treatment, 1-yr f/u (only for portion of completers)
| | Role functioning | return to work | any period of work during post-treatment year | 1-yr f/u
| | | work retention | actually working within 2 weeks of outcome interview | 1-yr f/u
Kole-Snijders 1999 ^169^ | controlled for biomedical status (using Medical Examination and Diagnostic Information Coding System MEDICS); psychopathology; Age | Emotional Functioning | Negative affect | BDI | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | | Fear Survey Schedule (FSS-III-R) | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | Pain Behavior | Checklist for Interpersonal Pain Behavior (CHIP) | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | | Pain Behavior Scale (PBS) | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | Pain cognitions | CSQ | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | | Multidimensional Pain Locus of Control Questionnaire (MPLC) | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | | PCL | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | Somatic anxiety | Nijmegen Hyperventilation Questionnaire | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Pain | pain intensity | MPQ | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | | VAS | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Physical Functioning | Activity tolerance | Behavioral Approach Tests of walking and riding a bicycle up to preset maximum time | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
Vendrig 2000 ^223^ | none reported | Emotional Functioning | somatic symptoms, distress, depression, etc. | MMPI | before treatment, post-treatment, 6-mo f/u
| | Pain | pain intensity and location | pain drawing | before treatment, 6-mo f/u
| | | | VAS | before treatment, 6-mo f/u
| | Pharmacoeconomic/healthcare use | meds and treatment | use of analgesics, medical or paramedical treatment for symptoms of whiplash associated disorder | 6-mo f/u
| | Physical Functioning | Self-reported Disability | Quebec Back Pain Disability Scale | before treatment, post-treatment, 6-mo f/u
| | Role functioning | return to work | (blank) | 6-mo f/u
Burns 2000 ^102^ | Trait anxiety assessed with Anxiety Content Scale of MMPI-2, defensiveness assessed with Lie scale of MMPI-2 | Emotional Functioning | Depression | BDI | pre- and post-treatment
| | Pain | Pain severity | Pain Severity subscale of MPI | pre- and post-treatment
| | Physical Functioning | Activity levels | MPI | pre- and post-treatment
| | | Lifting capacity | Progressive Isoinertial Lifting Evaluation (PILE) | pre-treatment, post-treatment
| | | Walking endurance | treadmill test | pre-treatment, post-treatment
Chapman 2000 ^50^ | Patient ratings of treatment helpfulness correlated with treatment cost | Pharmacoeconomic/healthcare use | Treatment costs | provided for all three centers | (blank)
Vendrig 2000 ^222^ | MMPI-2 scales; controlled for patient age, education, duration of pain | Emotional Functioning | Fear of movement | Isostation B200 (triaxial dynamometer) to measure maximal isometric extension | 2 wks prior to treatment, during treatment, at 6-month follow-up
| | Pain | pain intensity | Visual Analogue Scale | 2 wks prior to treatment, during treatment, at 6-month follow-up
| | Participant ratings of global improvement and satisfaction with treatment | Satisfaction with Treatment | Clinical Satisfaction Questionnaire | 6-month follow-up
| | | Self-rated emotional change | 5-pt Likert scale from “no emotional change” to “considerable emotional change” | 6-month follow up
| | Physical Functioning | Self-reported Disability | Quebec Back Pain Disability Scale | 2 wks prior to treatment, during treatment, at 6-month follow-up
| | Role Functioning \| Pharmacoeconomic/healthcare use | “Normal functioning” | Return to work, no use of analgesics to reduce pain symptoms, no medical or paramedical treatment for back pain | 6-month follow-up
Bendix 2000 ^78^ | treatment group, drop-outs | Pain | leg and back pain severity | severity of pain rated 0 to 10 | before treatment, 12-mo f/u
| | Participant ratings of global improvement and satisfaction with treatment | Subjective overall assessment of back problems | 5 pt scale: much worse to much better compared to before treatment | 12-mo f/u
| | Pharmacoeconomic/healthcare use | contacts with health care system | count | before treatment, 12-mo f/u
| | Physical Functioning | ADLs | 15 questions about back problem interference with ADLs (Manniches Rating Scale: same as Low Back Rating Scale) | before treatment, 12-mo f/u
| | Role functioning | ability to work | working or looking for work/education, disability pension status, etc. | before treatment, 12-mo f/u
| | | days of sick leave | count | before treatment, 12-mo f/u
Sterner 2001 ^213^ | 0 | Coping | Coping | Coping Resource Index | Before treatment, after treatment, at 6-month follow-up
| | Emotional Functioning | Depression | Beck Depression Index | Before treatment, after treatment, at 6-month follow-up
| | | Life Satisfaction | Life Satisfaction Questionnaire | Before treatment, after treatment, at 6-month follow-up
| | | Pain aspects, behavioural responses, activities | Multidimensional Pain Inventory | Before treatment, after treatment, at 6-month follow-up
| | Pain | pain intensity | VAS | Before treatment, after treatment, at 6-month follow-up
| | Participant ratings of global improvement and satisfaction with treatment | Evaluation of effects of treatment | Questionnaire including pt comparison of aspects of pain and symptoms before and after treatment, satisfaction with program, some patients' medical records were checked for stress reactions and crisis disorders (e.g., PTSD) | after treatment, 6-month follow-up
| | Role functioning | sick leave | working at least 50% time | Before treatment, after treatment, at 6-month follow-up
Mayer 2001 ^181^ | age (5 groups: <25 yrs, 25-34, 35-44, 45-54, 55+) | Litigation and claims | case settlement | yes/no | 1-yr f/u
| | Pharmacoeconomic/healthcare use | New surgery | New surgery to same area | 1-yr f/u
| | | Seeking treatment from new provider | % of pts, number of visits | 1-yr f/u
| | Role functioning | work retention | was working within 2-wks of f/u interview | 1-yr f/u
| | | work return | any return to work, also noted whether permanent modification of work, and whether with same employer | 1-yr f/u
| | Symptoms and adverse events | recurrent injury | injury to same area, with or without lost work time | 1-yr f/u
Jensen 2001 ^160^ | change in pain beliefs (Survey of Pain Attitudes), change in catastrophizing (CSQ catastrophizing scale), change in coping (Chronic Pain Coping Inventory); pain site, pre-treatment pain, employment status, pain duration, | Emotional Functioning | Depression | CES-D | pre-treatment, after treatment, 6-mo f/u, 12-mo f/u
| | Pain | pain intensity | average, least, and worst pain intensity over past week | pre-treatment, after treatment, 6-mo f/u, 12-mo f/u
| | Pharmacoeconomic/healthcare use | health care use | number of pain-related visits made to physicians during prior 3 months | pre-treatment, 6-mo f/u, 12-mo f/u
| | Physical Functioning | physical functioning | Roland Scale: both self-rated and as rated by patient's significant other | pre-treatment, after treatment, 6-mo f/u, 12-mo f/u
Skouen 2002 ^208^ | treatment and control groups; gender | Pharmacoeconomic/healthcare use | costs | economic returns for society from treatment at the clinic vs. treatment as usual | (blank)
| | Role functioning | return to work | National Health Insurance data on payments of sickness benefits, rehab benefits, or disability pension (absence of benefits = return to work) | monthly for 26 months after treatment
Vines 2000 ^225^ | none reported | Biological markers | immune function | changes in T lymphocyte proliferation after stimulation with Concanavalin A and Phytohemagglutinin; NK cell activity | baseline, week 4 of treatment
| | Emotional Functioning | Depression | BDI | baseline, week 4 of treatment
| | Pain | Pain intensity and affect | SF-MPQ | baseline, week 4 of treatment
| | Physical Functioning | Health behaviors (e.g., exercise, nutrition, relaxation) | Personal Lifestyle Activities Questionnaire (PLQ) | baseline, week 4 of treatment
Walsh 2002 ^231^ | correlations with outcome variables calculated for: PBQ Organic Pain Belief scale and PBQ Psychological Pain Belief scale | Emotional Functioning | Pain beliefs | Pain Beliefs Questionnaire (PBQ) | pre-treatment, post-treatment, 3-mo f/u
| | Physical Functioning | Disability | Oswestry Low Back Pain Disability Questionnaire | pre-treatment, post-treatment, 3-mo f/u (except Oswestry, which was offered only to a subset of pts and only at pre-treatment assessment)
| | | | Roland and Morris Disability Questionnaire (RMDQ) | pre-treatment, post-treatment, 3-mo f/u (except Oswestry, which was offered only to a subset of pts and only at pre-treatment assessment)
| | | | SF-36 | pre-treatment, post-treatment, 3-mo f/u (except Oswestry, which was offered only to a subset of pts and only at pre-treatment assessment)
Gatchel 2002 ^140^ | Coping style | Coping | Coping styles | Multidimensional Pain Inventory (MPI) | pre-treatment, post-treatment
| | Emotional Functioning | Depression | Beck Depression Inventory (BDI) | pre-treatment, post-treatment
| | Emotional Functioning Physical Functioning | Self-report mental and physical functioning | Medical Outcomes Short Form-36 Health-Status Survey (SF-36) | pre-treatment, post-treatment,
| | Pain | Pain | Pain Drawing Visual Analog (VAS) | pre-treatment, post-treatment
| | Pharmacoeconomic/healthcare use | Medication usage | use of opiates, antidepressants, benzodiazepines | pre-treatment, post-treatment
| | Physical Functioning | Perceived functional disabilities caused by pain | Owestry Pain Disability Questionnaire | pre-treatment, post-treatment
| | | Perceived pain and disability | Dallas Pain and Disability Questionnaire (DPDQ) | pre-treatment, post-treatment
Gustafsson 2002 ^13^ | treatment vs. control | Emotional Functioning Physical Functioning | Psychological, social, and behavioral aspects of pain | MPI | before treatment, after treatment, 3-mo f/u, 12-mo f/u
| | Pain | pain intensity and location | pain drawing | before treatment, after treatment, 3-mo f/u, 12-mo f/u
| | | | VAS | before treatment, after treatment, 3-mo f/u, 12-mo f/u
| | Physical Functioning | Qualities of movement in patients with psychosomatic or psychiatric symptoms | Body Awareness Scale-Health (BAS-H) | before treatment, after treatment, 3-mo f/u, 12-mo f/u
| | | Quality of Life | Quality of Life Scale (QLS) | before treatment, after treatment, 3-mo f/u, 12-mo f/u
Burns 2003 ^106^ | changes over course of treatment | Emotional Functioning | Depression | BDI | pre-treatment, mid-treatment, post-treatment
| | | pain catastrophizing | Coping Strategies Questionnaire Catastrophizing subscale | pre-treatment, mid-treatment, post-treatment
| | | Pain Helplessness | Arthritis Helplessness Index adapted by replacing “Arthritis” with “Pain” in questions | pre-treatment, mid-treatment, post-treatment
| | Pain \| Emotional Functioning | Pain severity, interference in daily functioning attributed to pain and ability to engage in everyday activities | MPI | pre-treatment, mid-treatment, post-treatment
Bailey 2003 ^94^ | physical and sexual abuse history; sex | Emotional Functioning | Anxiety | Beck Anxiety Inventory (BAI) | Intake, discharge, 6-mo f/u, 12-mo f/u
| | | Depression | BDI | Intake, discharge, 6-mo f/u, 12-mo f/u
| | Pain | Pain | MPI | Intake, discharge, 6-mo f/u, 12-mo f/u
| | Pharmacoeconomic/healthcare use | Healthcare use | 4 self-report questions (health care visits, hospitalizations, surgeries, emergency room visits) | Intake, 6-mo f/u, 12-mo f/u
| | Role functioning | Work status | self-report | Intake, 6-mo f/u, 12-mo f/u
Turner-Stokes 2003 ^76^ | none | Emotional Functioning | Depression | BDI | baseline, post-treatment, 6-mo f/u, 12-mo f/u
| | | State anxiety | Speilberger State-Trait Anxiety Inventory (STAI) | baseline, post-treatment, 6-mo f/u, 12-mo f/u
| | Pharmacoeconomic/healthcare use | analgesic medication consumption | self-reported number of pain killer and anti-inflammatory tablets consumed weekly | baseline, post-treatment, 6-mo f/u, 12-mo f/u
| | Physical Functioning | interference of pain with daily activities; sense of control over pain; physical and social activity inside and outside the home, pain severity | WHYMPI | baseline, post-treatment, 3-mo f/u, 6-mo f/u, 12-mo f/u
Robbins 2003 ^38^ | dropouts vs. completers; none others reported | Coping | Coping styles | Multidimensional Pain Inventory (MPI) | pre-treatment, post-treatment, 1-year follow-up
| | Emotional Functioning | Depression | Beck Depression Inventory (BDI) | pre-treatment, post-treatment, 1-year follow-up
| | Emotional Functioning \| Physical Functioning | Self-report mental and physical functioning | Medical Outcomes Short Form-36 Health-Status Survey | pre-treatment, post-treatment, 1-year follow-up
| | Pain | Pain | Pain Drawing Visual Analog (VAS) | pre-treatment, post-treatment, 1-year follow-up
| | Pharmacoeconomic/healthcare use | health care use | health care visits and emergency room visits | number of visits during 1-yr f/u period
| | | Medication usage | use of opiates, antidepressants, benzodiazepines | pre-treatment, one-year follow-up
| | Physical Functioning | Perceived functional disabilities caused by pain | Owestry Pain Disability Questionnaire | pre-treatment, post-treatment, 1-year follow-up
| | | Perceived pain and disability | Dallas Pain Questionnaire (DPQ) | pre-treatment, post-treatment, 1-year follow-up
| | Role functioning | vocational status | currently working, no work due to original injury, no work for other reason | pre-treatment, one-year follow-up
Jensen 2003 ^14^ | change in Pain Stages of Change Questionnaire (PSOCQ), clinic (UW and FM); controlled for pre-treatment pain severity | Coping | Pain coping | Chronic Pain Coping Inventory (CPCI) | pre-treatment, post-treatment, f/u (1 mo f/u for FM sample, 6 mos for UW)
| | Emotional Functioning | Depression | CES-D | pre-treatment, post-treatment, f/u (1 mo f/u for FM sample, 6 mos for UW)
| | Pain | Pain severity | average, worst, least pain intensity on 0-10 scale | pre-treatment, post-treatment, f/u (1 mo f/u for FM sample, 6 mos for UW)
| | | | WHYMPI | pre-treatment, post-treatment, f/u (1 mo f/u for FM sample, 6 mos for UW)
| | Physical Functioning | Physical disability and activity interference | Roland-Morris Disability Questionnaire (RMDQ) | pre-treatment, post-treatment, f/u (1 mo f/u for FM sample, 6 mos for UW)
| | | | WHYMPI | pre-treatment, post-treatment, f/u (1 mo f/u for FM sample, 6 mos for UW)
Ciechanowski 2003 ^113^ | Attachment style using Relationship Scale Questionnaire (RSQ); gender and age included in some models | Emotional Functioning | catastrophizing | Coping Strategies Questionnaire (CSQ-C) | pre-treatment, 12-mo f/u
| | | Depression | CES-D | pre-treatment, 12-mo f/u
| | Pain | pain intensity | average, least, and worst pain intensity over past week | pre-treatment, 12-mo f/u
| | Pharmacoeconomic/healthcare use | health care use | number of pain-related visits made to physicians during prior 3 months | pre-treatment, 12-mo f/u
| | Physical Functioning | physical functioning | Roland Scale: self-rated | pre-treatment, 12-mo f/u
Burns 2003 ^105^ | changes in outcome measures | Emotional Functioning | Depression | BDI | pre-treatment, mid-treatment, post-treatment
| | | pain catastrophizing | Pain Catastrophizing scale (PCS) | pre-treatment, mid-treatment, post-treatment
| | | Pain Helplessness | Arthritis Helplessness Index adapted by replacing “Arthritis” with “Pain” in questions | pre-treatment, mid-treatment, post-treatment
| | | Pain-related anxiety and fear | Pain Anxiety Symptoms Scale short form (PASS-20) | pre-treatment, mid-treatment, post-treatment
| | Pain \| Emotional Functioning | Pain severity, interference in daily functioning attributed to pain and ability to engage in everyday activities | MPI | pre-treatment, mid-treatment, post-treatment
Evans 2001 ^128^ | Recurrent injury vs. non-recurrent injury | Litigation and claims | claim settlement | settlement of pt's disability-related compensation claim | 1-yr
| | Pharmacoeconomic/healthcare use | new healthcare provider | % of pts seeking healthcare from a new provider, suggesting dissatisfaction with health status and disability determinations by current treating and referring doctors | 1-yr
| | | New surgery | surgery to the original compensable injured area during the post-treatment year | 1-yr
| | Physical Functioning | new injury | new injury claim to the original compensable injured area resulting in lost time from work | 1-yr
| | Role functioning | return to work | any period of work during post-treatment year; also measured months worked since treatment | 1-yr f/u
| | | work retention | employed at time of 1-yr f/u | 1-yr f/u
Lang 2003 ^171^ | none reported | Emotional Functioning | Depression | Allgemeine Depressionsskala | pre-treatment, 6-mo f/u
| | Pain | Pain intensity and interference with function | Brief Pain Inventory | pre-treatment, 6-mo f/u
| | Participant ratings of global improvement and satisfaction with treatment | “How do you estimate the restriction in your whole life situation due to pain as compared to the time before the beginning of the study?” | better, unchanged, or worse | 6-mo f/u
| | Physical Functioning | Health-related Quality of Life | SF-36 | pre-treatment, 6-mo f/u
| | Role functioning | days off from work in the last 3 months | self-reported | pre-treatment, 6-mo f/u
Mayer 2002 ^186^ | cervical fusion status (yes/no) | Litigation and claims | case settlement | yes/no | 1-yr f/u
| | Pharmacoeconomic/healthcare use | New surgery | New surgery to same area | 1-yr f/u
| | | Seeking treatment from new provider | % of pts, number of visits | 1-yr f/u
| | Role functioning | work retention | was working within 2-wks of f/u interview | 1-yr f/u
| | | work return | any return to work, also noted whether permanent modification of work, and whether with same employer | 1-yr f/u
| | Symptoms and adverse events | recurrent injury | injury to same area, with or without lost work time | 1-yr f/u
Glenn 2003 ^143^ | changes over course of treatment | Emotional Functioning | Depression | BDI | pre-treatment, mid-treatment, post-treatment
| | | Pain self-management stage of change | PSOCQ | pre-treatment, mid-treatment, post-treatment
| | Pain \| Emotional Functioning | Pain severity, interference in daily functioning attributed to pain and ability to engage in everyday activities | MPI | pre-treatment, mid-treatment, post-treatment
Currie 2003 ^15^ | none reported | Emotional Functioning | Self-management | Self-Control Scale (SCS) | pre-treatment, post-treatment, 3-mo f/u, 12-mo f/u
| | Other | Addiction | Addiction Severity Indices (includes employment--days with employment problems) | pre-treatment, post-treatment, 3-mo f/u, 12-mo f/u
| | Pain | Pain severity and quality | MPQ-PRI | pre-treatment, post-treatment, 3-mo f/u, 12-mo f/u
| | Pharmacoeconomic/healthcare use | Medication | MQS | pre-treatment, post-treatment, 3-mo f/u, 12-mo f/u
| | Physical Functioning | psychosocial impact of pain | MPI | pre-treatment, post-treatment, 3-mo f/u, 12-mo f/u
Edwards 2003 ^124^ | Pre-treatment Ischemic Pain Tolerance: Experimental pain response to assess behavioral responses to a standardized noxious stimulus; sex; pre-treatment MPI scales | Pain \| Emotional Functioning | Pain severity, interference, general activity, affective distress | MPI | before and after treatment program
Walsh 2004 ^232^ | None reported | Emotional Functioning | Self Efficacy on 10 classes of activity (household, leisure, work, etc.) | Self Efficacy Questionnaire | baseline, after treatment, 9 months post-treatment
| | Physical Functioning | Disability | Roland and Morris Disability Questionnaire | baseline, after treatment, 9 months post-treatment
| | | Walking performance | 5-Minute Walk Test | baseline, after treatment, 9 months post-treatment
| | Role functioning | Occupational Performance | Canadian Occupational Performance Measure--reported difficulties in occupational performance and satisfaction with performance | baseline, after treatment, 9 months post-treatment
Proctor 2004 ^200^ | whether pt had received treatment for the injury from a new provider in the year post-treatment; number of visits | Litigation and claims | case settlement | % reporting | 1-yr f/u
| | Pharmacoeconomic/healthcare use | new surgery in original area of injury | % reporting | 1-yr f/u
| | Physical Functioning | new injury claim after return to work | % reporting | 1-yr f/u
| | Role functioning | pt still working | % reporting | 1-yr f/u
| | | return to work | % reporting | 1-yr f/u
Olason 2004 ^196^ | none reported | Emotional Functioning | Anxiety/depression | numeric rating scale (self-estimated) | admission, discharge, 1-yr f/u
| | Pain | Pain | numeric rating scale (self-estimated) | admission, discharge, 1-yr f/u
| | Pharmacoeconomic/healthcare use | analgesic meds use | opioids, NSAIDs, anti-depressants | admission, discharge, 1-yr f/u
| | Role functioning | Work status | working, receiving disability benefits | admission, discharge, 1-yr f/u, 3 to 6-yr f/u
Koopman 2004 ^170^ | trunk flexibility, sex, age, functional disability, reinterpretation of pain sensations | Coping | Coping styles: catastrophizing, perceived pain control, denial of pain, positive self approach, reinterpretation of pain sensations, praying and hoping, distracting attention, becoming more active | CSQ | baseline, 12 weeks after admission, 1-yr follow-up
| | Emotional Functioning | Symptoms: depression, generalized fear, psychoneuroticism | SCL-90 | baseline, 12 weeks after admission, 1-yr follow-up
| | Physical Functioning | Functional disability | Quebec Back Pain Disability Scale | baseline, 12 weeks after admission, 1-yr follow-up
| | | Physical Function | muscular strength, cardiovascular fitness, trunk flexibility | baseline, 12 weeks after admission, 1-yr follow-up
| | Role functioning | return to work | hours of work per week; percentage work of appointment (i.e., depending on whether it was initially a full-time job or a part-time job), work status (includes return to old job without adaptations, return to old job with temporary or permanent adaptations | baseline, 12 weeks after admission, 6 mos after discharge, 1-yr follow-up
Cedraschi 2004 ^16^ | Participants vs. control groups | Clinician or surrogate ratings of global improvement | Physician evaluation of pain | Tender points, myalgic score, total physician score | baseline, 6-mo f/u
| | Participant ratings of global improvement and satisfaction with treatment | Patient satisfaction | Likert scales for PT, symptom control, psychosocial factors, and information | 6-mo f/u
| | Physical Functioning | continuation of activity | whether pts had continued swimming pool exercises, resumed an activity they had given up, or engaged in a new activity | 6-mo f/u
| | | functional and symptomatic consequences of FM | Fibromyalgia Impact Questionnaire | baseline, 6-mo f/u
| | | Quality of Life | Psychological General Well-Being index (PGWB) | baseline, 6-mo f/u
| | | | SF-36 | baseline, 6-mo f/u
Wasan 2004 ^233^ | ECT vs. no ECT | Emotional Functioning | depression change | Montgomery-Asberg Depression Inventory (MA) | multiple during stay
| | Pain | pain change | daily record by attending and nursing staff of patient's pain rating on 0 to 10 scale | daily during treatment
| | Pharmacoeconomic/healthcare use | prescribed opioid dose | (blank) | admission/discharge
Magnusson 2004 ^27^ | MPP vs. pharma/Usual Care | Emotional Functioning Physical Functioning | physical and mental health | SF-36 | pre-treatment, discharge or 1-yr post-entry
| | Pain | Headache frequency | headache diary | pre-treatment, discharge or 1-yr post-entry
| | Physical Functioning | Headache Disability | Headache Disability Inventory (HDI) | pre-treatment, discharge or 1-yr post-entry
Storro 2004 ^214^ | 0 | Role functioning | On sick-list | Central sick-list kept by the Local National Insurance Office | 1, 3, 6, 12 months post treatment
Patrick 2004 ^197^ | age (45-54 yrs, 55-64 yrs); no reporting of original treatment/control groups | Pain | Current Pain Levels | MPQ | 13 yr f/u
| | Pharmacoeconomic/healthcare use | Post-treatment health use for pain | self-reported, type of provider/treatment, number of visits | 13 yr f/u
| | Physical Functioning | General Health Functioning | SF-36 | 13 yr f/u
| | | Pain interference | MPI: Interference and Negative Mood scales | 13 yr f/u
| | Role functioning | return to employment | Quantity (length of time as an employed worker or worker in the home since treatment); Quality (type of work done) | 13 yr f/u
Spinhoven 2004 ^211^ | catastrophizing, pain coping, internal pain control, external pain control | Emotional Functioning | Negative affect | BDI | pre-treatment, post-treatment, 12-mo f/u
| | | | Fear Survey Schedule (FSS-III-R) | pre-treatment, post-treatment, 12-mo f/u
| | | Pain Behavior | Checklist for Interpersonal Pain Behavior (CHIP) | pre-treatment, post-treatment, 12-mo f/u
| | | | Pain Behavior Scale (PBS) | pre-treatment, post-treatment, 12-mo f/u
| | Pain | pain intensity | Pain Rating Index of the MPQ | pre-treatment, post-treatment, 12-mo f/u
| | Physical Functioning | Activity tolerance | Behavioral Approach Tests of walking and riding a bicycle up to preset maximum time | pre-treatment, post-treatment, 12-mo f/u
Jousset 2004 ^162^ | treatment vs. control; difference in sick leave days post-treatment adjusted for presence of ergonomic program in workplace | Emotional Functioning | psychological profile | HADS | pre-treatment, 6-mo f/u
| | Pain | pain intensity | VAS | pre-treatment, 6-mo f/u
| | Pharmacoeconomic/healthcare use | Medication use | use of prescription medications | pre-treatment, 6-mo f/u
| | | other healthcare use | number of “pain treatments”--contacts with family physician, contacts with specialists | 6-mo f/u
| | Physical Functioning | Pain impact on life | Dallas Pain Questionnaire | pre-treatment, 6-mo f/u
| | | | Quebec Back Pain Disability | pre-treatment, 6-mo f/u
| | | physical parameters | Trunk flexibility, trunk strength, lifting capacity, endurance | pre-treatment, 6-mo f/u
| | Role functioning | sick leave | number of days of sick leave taken after program completion | 6-mo f/u
Rome 2004 ^205^ | pre-treatment use of opioids (yes/no; none, low-dose, high-dose) | Emotional Functioning | Depression | Center for Epidemiological Studies-Depression Scale (CES-D) | admission, dismissal
| | | pain catastrophizing | Coping Strategies Questionnaire (CSQ-C) | admission, dismissal
| | Pharmacoeconomic/healthcare use | opioid use | current dose calculated from pt self-report, medical records, medication logs | admission, dismissal
| | Physical Functioning | psychosocial functioning, activity levels, pain severity, pain interference with life | MPI | admission, dismissal
Vowles 2004 ^227^ | demographics, BDI, MPQ-SF, PASS, PDI, functional capacity | Role functioning | return to work | part-time or full-time work; job retraining, education | 6 months after treatment
Vollenbroek-Hutten 2004 ^226^ | MMPI-DLV used to classify pts into dysfunctionals, interpersonally distressed, adaptive copers, average; lumbar dynamometry at baseline used to divide pts into expected, normal, and inconsistent-grey zone or inconsistent-submaximal (performance is not maximal and assessment is probably not valid) | Emotional Functioning | Kinesiophobia | Tampa Scale | baseline, after 8-weeks treatment (or no-treatment), 4-mo later
| | | Psychological dysfunction | SCL-90 | baseline, after 8-weeks treatment (or no-treatment), 4-mo later
| | Physical Functioning | Disability | Roland Disability Questionnaire (RDQ) | baseline, after 8-weeks treatment (or no-treatment), 4-mo later
| | | Health-related Quality of Life | EuroQol (EQ5-D) | baseline, after 8-weeks treatment (or no-treatment), 4-mo later
| | | Physical condition | Astrand VO2 max, leg strength | baseline, after 8-weeks treatment (or no-treatment), 4-mo later
Kenny 2004 ^164^ | singing vs. listening to music vs. didn't attend singing | Emotional Functioning | Depression | Zung Depression Inventory | pre- and post-program, 6-mo f/u
| | | mood | Profile of Mood States | pre- and post-program
| | | pain-related cognitions | Pain Responses Self-Statements: catastrophizing scale, active coping scale | pre- and post-program, 6-mo f/u
| | | Patient belief in ability to engage in tasks despite pain | Pain Self-Efficacy Questionnaire | pre- and post-program, 6-mo f/u
| | Physical Functioning | Quality of Life, Pain tolerance | Oswestry Low Back Pain Disability Questionnaire | pre- and post-program, 6-mo f/u
Jensen 2004 ^17^ | change in Pain Stages of Change Questionnaire (PSOCQ), clinic (UW and FM); controlled for pre-treatment pain severity | Coping | Pain coping | Chronic Pain Coping Inventory (CPCI) | pre-treatment, post-treatment, 6-mo f/u
| | Emotional Functioning | Depression | CES-D | pre-treatment, post-treatment, 6-mo f/u
| | Pain | Pain severity | average, worst, least pain intensity on 0-10 scale | pre-treatment, post-treatment, 6-mo f/u
| | | | WHYMPI | pre-treatment, post-treatment, 6-mo f/u
| | Physical Functioning | Physical disability and activity interference | Roland-Morris Disability Questionnaire (RMDQ) | pre-treatment, post-treatment, 6-mo f/u
| | | | WHYMPI | pre-treatment, post-treatment, 6-mo f/u
Protas 2004 ^202^ | cervical vs. lumbar spine disorder; valid vs. invalid scores on pre-rehab aerobic capacity test (e.g., not strong enough to complete the test) | Emotional Functioning | psychosocial | BDI | intake, discharge, pain intensity also recorded at 1-yr f/u
| | | | MVAS | intake, discharge, pain intensity also recorded at 1-yr f/u
| | Litigation and claims | case settlement | % reporting | 1-yr f/u
| | Pain | psychosocial | pain intensity | intake, discharge, pain intensity also recorded at 1-yr f/u
| | Pharmacoeconomic/healthcare use | health utilization (new provider) | seeing new provider for same issue | 1-yr f/u
| | | new surgery to treated area | % reporting | 1-yr f/u
| | Physical Functioning | aerobic capacity | variety (heart rate, watts, predicted max VO2, perceived exertion) | intake, discharge
| | Role functioning | return to work | any work during f/u | 1-yr f/u
| | | work retention | “remained working” at time of f/u | 1-yr f/u
| | Symptoms and adverse events | recurrent injury | % reporting | 1-yr f/u
Dysvik 2004 ^122^ | none reported | Coping | Coping Strategies | Ways of Coping Checklist (WCCL) | pre-treatment, post-treatment
| | Pain | pain intensity | VAS | pre-treatment, post-treatment
| | Physical Functioning | Health related quality of life | SF-36 | pre-treatment, post-treatment
| | | Quality of life now and in 5 years | Cantril's ladder | pre-treatment, post-treatment
Michaelson 2004 ^189^ | prediction of pain reduction using initial variables including MPI pain severity and affective distress, optimism, sociability, physical endurance, age, etc.; presented separately for pain location (neck vs. low-back) | Pain | average pain intensity over past week | VAS | pretreatment, post treatment, 12-mo f/u
Gross 2005 ^144^ | year of treatment (1999 vs. 2000); pre-admission health visits; months between injury and admission to rehab, previous back claims; adjusted for gender, diagnosis, duration of injury, physical demands rating, VAS, PDI, etc. | Role functioning | Recovery | time to claim closure following admission to rehab | (blank)
| | | return to work | days receiving time-loss benefits following admission to the rehab program | (blank)
| | Symptoms and adverse events | Recurrence | claim reopened, new back-related claim filed, subject restarted time-loss benefits | 1-yr f/u
Norrefalk 2005 ^192^ | Return to work prediction based on IDEA, pre-treatment pain intensity, somatic value of pain, disability rating index, etc. | Role functioning | Return to work, hours worked per day | reported by local social insurance office | 1-yr f/u
Keogh 2005 ^165^ | sex; pain, distress, catastrophizing | Emotional Functioning | Acceptance | Chronic Pain Acceptance Questionnaire (CPAQ) | pre-treatment, post-treatment, 3-mo f/u
| | | Emotional distress | BDI | pre-treatment, post-treatment, 3-mo f/u
| | | | Pain-related distress over past week | pre-treatment, post-treatment, 3-mo f/u
| | | | PASS | pre-treatment, post-treatment, 3-mo f/u
| | | | PCS | pre-treatment, post-treatment, 3-mo f/u
| | Pain | subjective pain | current intensity, usual intensity over past week | pre-treatment, post-treatment, 3-mo f/u
| | Physical Functioning | Disability | Sickness Impact Profile (SIP) | pre-treatment, post-treatment, 3-mo f/u
| | | pain-related behaviors | medication use, rest hours during day, hours slept at night | pre-treatment, post-treatment, 3-mo f/u
| | | physical performance | 10-minute walk; sit-to-stand trial (repetitions | pre-treatment, post-treatment, 3-mo f/u
| | | | sit-to-stand trial (repetitions | pre-treatment, post-treatment, 3-mo f/u
Gatchel 2005 ^141^ | 8 categories for marital status, sex, children/no children; age | Litigation and claims | claim settlement | settlement of pt's disability-related compensation claim | 1-yr
| | Pharmacoeconomic/healthcare use | new healthcare provider | % of pts seeking healthcare from a new provider, suggesting dissatisfaction with health status and disability determinations by current treating and referring doctors | 1-yr
| | | New surgery | surgery to the original compensable injured area during the post-treatment year | 1-yr
| | Role functioning | return to work | any period of work during post-treatment year | 1-yr f/u
| | | Work days lost | % yes | 1-yr f/u
| | | work retention | actually working within 2 weeks of outcome interview | 1-yr f/u
Burns 2005 ^107^ | changes over course of treatment | Emotional Functioning | Depression | BDI | pre-treatment, mid-treatment, post-treatment
| | | Pain self-management stage of change | PSOCQ | pre-treatment, mid-treatment, post-treatment
| | Pain \| Emotional Functioning | Pain severity, interference in daily functioning attributed to pain and ability to engage in everyday activities | MPI | pre-treatment, mid-treatment, post-treatment
Fishbain 2005 ^130^ | pre-treatment scores on Neuropathic Pain Scale and Beck Depression Inventory, demographic information, primary and secondary pain diagnoses, DSM-IV psychiatric diagnoses, pain location, prior surgeries, sex | Physical Functioning | Pain-associated Fatigue | Multidimensional Fatigue Inventory (MFI) | before and after treatment
Proctor 2005 ^201^ | treatment completers vs. non-completers | Litigation and claims | case settlement | % reporting | 1-yr f/u
| | Pharmacoeconomic/healthcare use | health utilization (new provider) | %; also, number of visits | 1-yr f/u
| | | New surgery to compensable area | % reporting | 1-yr f/u
| | Role functioning | hours working per week | % working full-time, 20-39 hrs per week, less than 20 hrs per week | 1-yr f/u
| | | work retention at 1-yr | % | 1-yr f/u
| | | work return | %; also recorded whether returned to same employer, returned to identical job | 1-yr f/u
| | Symptoms and adverse events | recurrent injury with lost work days | % reporting | 1-yr f/u
McCracken 2005 ^188^ | correlations with outcome variables calculated for: activity engagement, pain willingness, total acceptance | Emotional Functioning | Acceptance | Chronic Pain Acceptance Questionnaire (CPAQ) | assessment, pre-treatment, post-treatment, 3-mo f/u
| | | Emotional distress | BDI | assessment, pre-treatment, post-treatment, 3-mo f/u
| | | | PASS | assessment, pre-treatment, post-treatment, 3-mo f/u
| | | | PCS | assessment, pre-treatment, post-treatment, 3-mo f/u
| | Pain | subjective pain | current intensity, usual, lowest intensity over past week | assessment, pre-treatment, post-treatment, 3-mo f/u
| | Pharmacoeconomic/healthcare use | GP Visits | count over past 6 months | assessment, 3-mo f/u
| | Physical Functioning | Disability | Sickness Impact Profile (SIP) | assessment, pre-treatment, post-treatment, 3-mo f/u
| | | pain-related behaviors | medication use, rest hours during day, hours slept at night | assessment, pre-treatment, post-treatment, 3-mo f/u
| | | physical performance | 10-minute walk; sit-to-stand trial (repetitions | pre-treatment, post-treatment, 3-mo f/u
| | | | sit-to-stand trial (repetitions | pre-treatment, post-treatment, 3-mo f/u
| | Role functioning | Working | % of patients | assessment, pre-treatment, 3-mo f/u
Masuda 2005 ^40^ | with or without thermal therapy, number of pain behaviors vs. outcome, VAS vs. outcome | Emotional Functioning | Anger | Cornell Medical Index | admission and discharge
| | | Depression | Zung Self-Rating Depression Scale | admission and discharge
| | | Pain behaviors (11 noted, including request for analgesics, request for compress or massage, complaints about stubborn pain, change in expression or posture due to pain, overreact to pain by gait disturbance, crying, hysterical reaction, etc.) | (blank) | one week after admission, one week before discharge
| | Pain | Pain | VAS | one week after admission, one week before discharge
| | Physical Functioning | Sleep quality | sleep score | admission and discharge
| | Role functioning | return to work | yes/no | 2 years post-discharge
Dysvik 2005 ^123^ | none reported | Coping | Coping Strategies | Ways of Coping Checklist (WCCL) | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Pain | location and distribution of pain | body diagrams | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | pain intensity | VAS | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Pharmacoeconomic/healthcare use | Analgesic use | 5-pt Likert scale of frequency of use over past month | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | Physical Functioning | Health related quality of life | SF-36 | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
| | | Quality of life now and in 5 years | Cantril's ladder | pre-treatment, post-treatment, 6-mo f/u, 12-mo f/u
Skouen 2006 ^29^ | treatment and control groups; gender | Role functioning | return to work | National Health Insurance data on payments of sickness benefits, rehab benefits, or disability pension (absence of benefits = return to work) | monthly for 54 months after treatment
Kaapa 2006 ^163^ | rehab program | Emotional Functioning | belief of working ability after 2 years | 0 to 10 scale | baseline, post-treatment, 6-mo f/u, 12-mo f/u, 24-mo f/u
| | | Depression | Depression Scale (DEPS) | baseline, post-treatment, 6-mo f/u, 12-mo f/u, 24-mo f/u
| | Pain | pain (low back and sciatic) | scale of 0 to 10 | baseline, post-treatment, 6-mo f/u, 12-mo f/u, 24-mo f/u
| | Participant ratings of global improvement and satisfaction with treatment | general well-being after back rehab | questionnaire with 8 statements | post-treatment
| | Pharmacoeconomic/healthcare use | healthcare consumption during past 12 mo | total number of visits to physician, PT, nurse, etc. | baseline, 12-mo f/u, 24-mo f/u
| | Physical Functioning | back disability | ODI | baseline, post-treatment, 6-mo f/u, 12-mo f/u, 24-mo f/u
| | Role functioning | sick leave due to back pain | 0 days, 1-30 days, more than 30 days | 12-mo f/u, 24-mo f/u
| | | subjective working capacity | scale of 0 to 10 | baseline, post-treatment, 6-mo f/u, 12-mo f/u, 24-mo f/u
Norrefalk 2006 ^193^ | native Swedes vs. immigrants | Pain | pain intensity | VAS | pre-treatment, 3-yr f/u
| | Pharmacoeconomic/healthcare use | reduction in analgesic use | self-reported consumption | pre-treatment, 3-yr f/u
| | Physical Functioning | activity level | estimated level of activity (self-report | pre-treatment, 3-yr f/u
| | Role functioning | Return to work, hours worked per day | reported by local social insurance office | 1-yr f/u
Maclaren 2006 ^176^ | opioid use at discharge and intake | Emotional Functioning | Depression | BDI | pretreatment, discharge
| | Pain | pain intensity | MPQ-SF | pretreatment, discharge
| | Physical Functioning | patients' perceived level of impairment | PDI | pretreatment, discharge
| | | Physical capacity | standardized functional capacity evaluation including lifting and carrying tasks | pretreatment, discharge
| | Role functioning | return to work | self-reported; full-time, part-time; structured job retraining counted as full-time, retiring counted as not working | 6-mos post discharge
Buchner 2007 ^100^ | age: 18-34, 35-50, 51-65 | Pain | pain intensity | VAS | before treatment, 6-mo f/u
| | Participant ratings of global improvement and satisfaction with treatment | Satisfaction with therapy | Likert scale | 6-mo f/u
| | Physical Functioning | Functional back capacity | FFbH | before treatment, 6-mo f/u
| | | Health related quality of life | SF-36 | before treatment, 6-mo f/u
| | Role functioning | return to work | % of pts | 6-mo f/u
Scerri 2006 ^206^ | INTERMED scores, radiological structural abnormalities (assessed as predictors of success/failure post-treatment) | Pain | Pain severity | VAS | before treatment
| | Role functioning | sick leave duration/return to work | working full-time, part-time, or not at all; sick leave duration before and after rehab | after rehab: 3 wk f/u, 3 mo f/u, 12 mo-f/u
Hatten 2006 ^146^ | health care visits and emergency room visits (pre-treatment? not well described); demographics | Emotional Functioning Physical Functioning | Self-report mental and physical functioning | Medical Outcomes Short Form-36 Health-Status Survey | pre-treatment, post-treatment (or 6-mos, for non-MPP groups)
| | Pain | Pain | Pain Drawing Analog (PDA) | pre-treatment, post-treatment (or 6-mos, for non-MPP groups)
| | Pharmacoeconomic/healthcare use | Medication usage | use of opiates, antidepressants, benzodiazepines | pre-treatment, post-treatment (or 6-mos, for non-MPP groups)
| | | Treatment costs | costs of treatments at pain center, pharmaceuticals prescribed at pain center, etc. | treatment duration (or 6 mos in non-MPP groups)
| | Physical Functioning | Perceived functional disabilities caused by pain | Owestry Pain Disability Questionnaire | pre-treatment, post-treatment (or 6-mos, for non-MPP groups)
| | | Perceived pain and disability | Dallas Pain Questionnaire (DPQ) | pre-treatment, post-treatment (or 6-mos, for non-MPP groups)
| | | Quality of Life | Brazier et al SF-36 Conversion Algorithm Model 10 | pre-treatment, post-treatment (or 6-mos, for non-MPP groups)
| | Role functioning | vocational status | currently working, no work due to original injury, no work for other reason; | pre-treatment, post-treatment (or 6-mos, for non-MPP groups)
Buchner 2006 ^99^ | location of pain: neck or low-back | Pain | pain intensity | VAS | before treatment, 6-mo f/u
| | Participant ratings of global improvement and satisfaction with treatment | Satisfaction with therapy | Likert scale | 6-mo f/u
| | Physical Functioning | Functional back capacity | FFbH | before treatment, 6-mo f/u
| | | Health related quality of life | SF-36 | before treatment, 6-mo f/u
| | Role functioning | return to work | % of pts | 6-mo f/u
Angst 2006 ^18^ | Back pain vs. FM | Coping | Coping Strategies | CSQ | entry, discharge, 3-mo f/u, 6-mo f/u
| | Emotional Functioning | affective health (anxiety and depression) | HADS | entry, discharge, 3-mo f/u, 6-mo f/u
| | Emotional Functioning Physical Functioning | Symptoms and functioning | SF-36 | entry, discharge, 3-mo f/u, 6-mo f/u
| | Pain \| Emotional Functioning | Pain symptoms/disability, activity, behavior, mood, social relationships | WHYMPI | entry, discharge, 3-mo f/u, 6-mo f/u
| | Pharmacoeconomic/healthcare use | Medication | medical records | entry, discharge
Huge 2006 ^154^ | none reported | Emotional Functioning | depressive symptoms | CES-D | assessment, 1-yr f/u
| | Pain | Pain | Numeric rating Scale scores | assessment, 1-yr f/u
| | Pharmacoeconomic/healthcare use | Use of health system | drug medication, visits to attending physician, frequency of treatments related to pain, inpatient pain treatment during 6 mos prior to 1-yr f/u, number of physicians consulted in the 6 mos prior to 1-yr f/u | pre, post
| | Physical Functioning | Health related quality of life | SF-36 | assessment, 1-yr f/u
| | | Pain-related interference with life | PDI | assessment, 1-yr f/u
Mayer 2006 ^182^ | obesity (5 groups--normal, overweight, obese I, II, III--based on BMI) | Emotional Functioning | psychological measures | BDI | pre-treatment, post-treatment
| | | | MVAS | pre-treatment, post-treatment
| | | | pain drawing | pre-treatment, post-treatment
| | Litigation and claims | case settlement | yes/no | 1-yr f/u
| | Pharmacoeconomic/healthcare use | New surgery | New surgery to same area | 1-yr f/u
| | | Seeking treatment from new provider | % of pts, number of visits | 1-yr f/u
| | Role functioning | work retention | was working within 2-wks of f/u interview | 1-yr f/u
| | | work return | any return to work, also noted whether permanent modification of work, and whether with same employer | 1-yr f/u
| | Symptoms and adverse events | recurrent injury | injury to same area, with or without lost work time | 1-yr f/u
Hooten 2007 ^19^ | 0 | Emotional Functioning | Depression | Center for Epidemiological Studies-Depression Scale (CES-D) | admission, dismissal
| | | pain catastrophizing | Coping Strategies Questionnaire (CSQ-C) | admission, dismissal
| | Pain | pain severity and affective characteristics | MPI | admission, dismissal
| | Pharmacoeconomic/healthcare use | Medication use | % using opioids, muscle relaxants, NSAIDS, benzodiazepines, antidepressants, mood stabilizers, antispychotics | admission, dismissal
| | Physical Functioning | physical functioning, health perception, social functioning | SF-36 | admission, dismissal
Jensen 2007 ^161^ | change in pain beliefs (Survey of Pain Attitudes), change in catastrophizing (CSQ catastrophizing scale), change in coping (Chronic Pain Coping Inventory) | Emotional Functioning | Depression | CES-D | pre-treatment, after treatment, 12-mo f/u
| | Pain | pain intensity | average, least, and worst pain intensity over past week | pre-treatment, after treatment, 12-mo f/u
| | Physical Functioning | physical functioning | Roland-Morris Disability Questionnaire (RMDQ) | pre-treatment, after treatment, 12-mo f/u
Norrefalk 2007 ^194^ | 0 | Pain | pain intensity/activity | “no pain” to “pain that demands rest such as sitting or lying down” | before treatment, 6-year follow-up
| | Pharmacoeconomic/healthcare use | consumption of analgesics | “no use of analgesics” to “overuse of analgesics” | before treatment, 6-year follow-up
| | Role functioning | return to work | 50% time or more | before treatment, 6 years later
Vowles 2007 ^228^ | correlations with outcome variables calculated for: depression, pain-related anxiety, physical disability, psychosocial disability, daily rest due to pain, timed walk, sit-to-stand | Emotional Functioning | Acceptance | Chronic Pain Acceptance Questionnaire (CPAQ) | pre-treatment, post-treatment, 3-mo f/u
| | | catastrophizing | PCS | pre-treatment, post-treatment, 3-mo f/u
| | | Depression and general emotional distress; pain-related anxiety and avoidance | BDI | pre-treatment, post-treatment, 3-mo f/u
| | | | PASS (Pain Anxiety Sickness Scale) | pre-treatment, post-treatment, 3-mo f/u
| | Pain | subjective pain | average over past week | pre-treatment, post-treatment, 3-mo f/u
| | Pharmacoeconomic/healthcare use | GP Visits | count over past 6 months | pre-treatment, post-treatment, 3-mo f/u
| | Physical Functioning | Disability | Sickness Impact Profile (SIP) | pre-treatment, post-treatment, 3-mo f/u
| | | Hours resting and sleeping during day | self-report | pre-treatment, post-treatment, 3-mo f/u
| | | physical performance | 10-minute walk; sit-to-stand trial (repetitions | pre-treatment, post-treatment, 3-mo f/u
| | | | sit-to-stand trial (repetitions | (blank)
| | Role functioning | Working | % of patients | pre-treatment, post-treatment, 3-mo f/u
Bliokas 2007 ^98^ | preprogram pain intensity, pre-program activity diary, pre-program kinesiophobia, treatment vs. waitlist, regular treatment vs. treatment plus graded exposure | Emotional Functioning | Depression and anxiety | DASS | pre-treatment, post-treatment
| | | Fear of Movement/Reinjury | Tampa Scale for kinesiophobia | pre-treatment, post-treatment
| | | Pain self-efficacy | PSEQ | pre-treatment, post-treatment
| | Pain | pain intensity | VAS | pre-treatment, post-treatment
| | Physical Functioning | activity level | Activity diary | pre-treatment, post-treatment
| | | mobility | six-minute walk test | (blank)
| | | Pain disability | Pain disability index (PDI) | pre-treatment, post-treatment
Dunstan 2007 ^121^ | work participation at pre-program | Emotional Functioning | Cognitions | Pain Catastrophizing Scale | pre- and post-program
| | | | Pain Self-Efficacy Questionnaire | pre- and post-program
| | | | Tampa Kinesiophobia Scale | pre- and post-program
| | | mood | Depression, Anxiety, and Stress scales (DASS) | pre- and post-program
| | Pain | Pain severity | self-report numerical scale | pre- and post-program
| | Physical Functioning | Disability | Modified Roland and Morris Questionnaire | pre- and post-program
| | | physical functioning | sitting (number of minutes, up to one hour); standing (number of minutes, up to one hour); walking (km per daily walk); lifting (kg from floor to waist) | pre- and post-program
| | Role functioning | Work disability and work resumption | participant's medically certified capacity for work; paid work participation | pre-program, post-program, 6-month f/u
Man 2007 ^177^ | none reported | Emotional Functioning | catastrophizing | PCS | baseline, 1-mo f/u, 6-mo f/u, 12 mo f/u
| | | Depression and anxiety | HAD Scale | baseline, 1-mo f/u, 6-mo f/u, 12 mo f/u
| | | Self-ability to deal with daily activities | PSEQ | baseline, 1-mo f/u, 6-mo f/u, 12 mo f/u
| | Pain | Pain | VAS | baseline, 1-mo f/u, 6-mo f/u, 12 mo f/u
| | Pharmacoeconomic/healthcare use | analgesic consumption | (blank) | baseline, 1-mo f/u, 6-mo f/u, 12 mo f/u
| | Physical Functioning | general health-related quality of life | SF-36 | baseline, 1-mo f/u, 6-mo f/u, 12 mo f/u
| | | physical activities | (blank) | baseline, 1-mo f/u, 6-mo f/u, 12 mo f/u
| | Role functioning | subjective performance and satisfaction in daily activities | Canadian Occupational Performance Measure (COPM) | baseline, 1-mo f/u, 6-mo f/u, 12 mo f/u
| | | Work status | (blank) | baseline, 1-mo f/u, 6-mo f/u, 12 mo f/u
Suoyrjo 2008 ^215^ | neck vs. back pain vs. non-rehab; adjusted for sex, age, occupational status, and rehab year | Pharmacoeconomic/healthcare use | purchase of analgesics | national data of out-patient prescriptions for opioids and NSAIDs | eight-yr period: 3 years before rehab, year of rehab, 4 years post rehab
| | Role functioning | Disability pensions | Finnish Centre of Pensions | all years of the study (1994 through 2006)
| | | sickness absence | national insurance data | eight-yr period: 3 years before rehab, year of rehab, 4 years post rehab
Wormgoor 2008 ^236^ | male vs. female for some; diagnostic category | Emotional Functioning | Mental distress | Anxiety, Depression, and irritability (ADI) | baseline, 6-mo f/u
| | Pain | pain intensity | 0 to 100 | baseline, 6-mo f/u
| | Physical Functioning | aerobic capacity | percentage of normal | baseline, admission, discharge, 6-mo f/u
| | | functioning | lifting capability, jogging capability | baseline, admission, discharge, 6-mo f/u (varies by measure)
| | | | Oswestry | baseline, admission, discharge, 6-mo f/u (varies by measure)
| | | lumbar flexion | percentage from normal | baseline, 6-mo f/u
| | Role functioning | work ability | >= 25% | baseline, 6-mo f/u
Ersek 2008 ^127^ | treatment vs. control only | Coping | pain-related cognitions and coping | Chronic Pain Coping Inventory | baseline, post-intervention, 1 year
| | Emotional Functioning | Depression | Geriatric Depression Scale | baseline, post-intervention, 1 year
| | | pain-related cognitions and coping | Arthritis Self-Efficacy Scale (modified for Pain) | baseline, post-intervention, 1 year
| | | | Coping Strategies Questionnaire Catastrophizing subscale | baseline, post-intervention, 1 year
| | Pain | pain intensity | Brief Pain Inventory | baseline, post-intervention, 6 mos, 1 year
| | Pharmacoeconomic/healthcare use | Medication use | yes/no on 4 types: acetaminophen, NSAIDs, opioids, other/adjuvants (includes antidepressants used for pain, gabapentin, corticosteroids, topical preparations) | baseline, post-intervention, 1 year
| | Physical Functioning | Disability | Roland-Morris Disability Questionnaire | baseline, post-intervention, 6 mos, 1 year
| | | Pain interference | Brief Pain Inventory | baseline, post-intervention, 6 mos, 1 year
Buchner 2007 ^101^ | degree of chronicity: used classification of von Korff et al. which includes pain intensity, pain frequency, time since onset, disability due to pain, and disability days | Pain | pain intensity | VAS | before treatment, 6-mo f/u
| | Participant ratings of global improvement and satisfaction with treatment | Satisfaction with therapy | Likert scale | 6-mo f/u
| | Physical Functioning | Functional back capacity | FFbH | before treatment, 6-mo f/u
| | | Health related quality of life | SF-36 | before treatment, 6-mo f/u
| | Role functioning | return to work | % of pts | 6-mo f/u
Norrefalk 2008 ^195^ | some results presented by white-collar and blue-collar workers, immigrants and native Swedes | Pharmacoeconomic/healthcare use | economic costs and benefits | net benefit in Euros, expressed as multiple of cost of running the program | (blank)
| | Role functioning | return to work | full-time work, part-time work, etc., from Social Insurance office | 1-yr f/u
Wang 2008 ^47^ | TNF-alpha positive | Biological markers | Cytokine levels in serum | TNF-α values greater than 2 pg/mL were considered as positive | beginning of study, day 10, day 21, 6-mo f/u
| | Pain | pain intensity | VAS | beginning of study, day 10, day 21, 6-mo f/u
| | Physical Functioning | pain-related disability | Roland and Morris Disability Questionnaire | beginning of study, day 10, day 21, 6-mo f/u
Vowles 2008 ^229^ | correlations with outcome variables calculated for: acceptance and values-based action | Emotional Functioning | Acceptance | CPAQ | pre-treatment, post-treatment, 3-mo f/u
| | | Depression | British Columbia Major Depression Inventory | pre-treatment, post-treatment, 3-mo f/u
| | | pain-related anxiety | PASS-20 | pre-treatment, post-treatment, 3-mo f/u
| | Other | values-based action | Chronic Pain Values Inventory | pre-treatment, post-treatment, 3-mo f/u
| | Pain | Pain | 0-10 numerical scale | pre-treatment, post-treatment, 3-mo f/u
| | Pharmacoeconomic/healthcare use | Medical Visits past 6 mos | self-report | pre-treatment, 3-mo f/u
| | | Medication use | number of different types | pre-treatment, 3-mo f/u
| | Physical Functioning | Disability | SIP | pre-treatment, post-treatment, 3-mo f/u
| | | physical performance | 10-minute walk; sit-to-stand trial (repetitions | pre-treatment, post-treatment, 3-mo f/u
| | | | sit-to-stand trial (repetitions | pre-treatment, post-treatment, 3-mo f/u
Crisostomo 2008 ^116^ | lumbar spine surgery history (lumbar spinal fusion, lumbar spinal surgery other than fusion, no lumbar spine surgery) | Emotional Functioning | Depression | Center for Epidemiological Studies-Depression Scale (CES-D) | admission, dismissal
| | | pain catastrophizing | Coping Strategies Questionnaire (CSQ-C) | admission, dismissal
| | Pain | pain severity and affective characteristics | MPI | admission, dismissal
| | Pharmacoeconomic/healthcare use | Medication use | % using opioids, muscle relaxants, NSAIDS, benzodiazepines | admission, dismissal
| | Physical Functioning | physical functioning | SF-36 | admission, dismissal
Mayer 2008 ^187^ | Chronic Widespread Pain status (yes/no) | Litigation and claims | case settlement | yes/no | 1-yr f/u
| | Pharmacoeconomic/healthcare use | New surgery | New surgery to same area | 1-yr f/u
| | | Seeking treatment from new provider | % of pts, number of visits | 1-yr f/u
| | Role functioning | work retention | was working within 2-wks of f/u interview | 1-yr f/u
| | | work return | any return to work, also noted whether permanent modification of work, and whether with same employer | 1-yr f/u
| | Symptoms and adverse events | recurrent injury | injury to same area, with or without lost work time | 1-yr f/u
Dersh 2008 ^119^ | Opioid Dependence Disorder | Litigation and claims | claim settlement | settlement of pt's disability-related compensation claim | 1-yr
| | Pharmacoeconomic/healthcare use | new healthcare provider | % of pts seeking healthcare from a new provider, suggesting dissatisfaction with health status and disability determinations by current treating and referring doctors | 1-yr
| | | New surgery | surgery to the original compensable injured area during the post-treatment year | 1-yr
| | Physical Functioning | new injury | new injury claim to the original compensable injured area resulting in lost time from work | 1-yr
| | Role functioning | return to work | any period of work during post-treatment year | 1-yr f/u
| | | work retention | employed at time of 1-yr f/u | 1-yr f/u
Wong 2009 ^235^ | none reported | Emotional Functioning | catastrophizing | Catastrophizing subscale of PCSQ | pre-treatment, 18-wk f/u, 44-wk f/u
| | | fear-avoidance beliefs | TSK | pre-treatment, 18-wk f/u, 44-wk f/u
| | | Psychological well-being | HADS | pre-treatment, 18-wk f/u, 44-wk f/u
| | | self-reported confidence performing activities in spite of pain | PSEQ | pre-treatment, 18-wk f/u, 44-wk f/u
| | Pharmacoeconomic/healthcare use | pain-related GP and consultant visits | number of visits in past 6 mos | pre-treatment, 44-wk f/u
| | Physical Functioning | impact of pain on physical daily activities | Modified SIP (24 items) | pre-treatment, 18-wk f/u, 44-wk f/u
| | | Quality of Life | Modified patient generated index (PGI) | pre-treatment, 18-wk f/u, 44-wk f/u
Hooten 2009 ^152^ | smoking status (current smoker, former smoker, never smoker) | Pain | pain severity and affective characteristics | MPI | admission, dismissal
| | Pharmacoeconomic/healthcare use | Medication use | % using opioids, muscle relaxants, NSAIDS, benzodiazepines | admission, dismissal
van Wilgen 2009 ^220^ | none reported | Emotional Functioning | beliefs regarding relationship between pain, activities, injuries, and re-injuries | Tampa Scale for Kinesiophobia (TSK) | beginning of waitlist period, admission, discharge, 6-mo f/u, 12-mo f/u
| | | Pain catastrophizing and negative self-efficacy | PCL (Pain Cognition List) | beginning of waitlist period, admission, discharge, 6-mo f/u, 12-mo f/u
| | | psychological symptoms | SCL-90 | beginning of waitlist period, admission, discharge, 6-mo f/u, 12-mo f/u
| | Pain | Pain | VAS scales | beginning of waitlist period, admission, discharge, 6-mo f/u, 12-mo f/u
| | Physical Functioning | Fatigue | VAS scales | beginning of waitlist period, admission, discharge, 6-mo f/u, 12-mo f/u
| | | general health and health-related quality of life | RAND-36 | beginning of waitlist period, admission, discharge, 6-mo f/u, 12-mo f/u
| | | physical functioning | 6 minute walk test | beginning of waitlist period, admission, discharge, 6-mo f/u, 12-mo f/u
| | | | 6 minute walk test, arm endurance, arm and leg strength | beginning of waitlist period, admission, discharge, 6-mo f/u, 12-mo f/u
| | | | arm and leg strength | beginning of waitlist period, admission, discharge, 6-mo f/u, 12-mo f/u
Suman 2009 ^20^ | None reported | Coping | Coping | Brief Pain Coping Inventory (BPCI) | pre-admission (3 to 8 mos before treatment); before treatment (1 day before); after treatment (day after); 2 mos after beginning of treatment, 5 mos after beginning treatment, 12 mos after beginning treatment
| | Emotional Functioning | Depression | CES-D | pre-admission (3 to 8 mos before treatment); before treatment (1 day before); after treatment (day after); 2 mos after beginning of treatment, 5 mos after beginning treatment, 12 mos after beginning treatment
| | Pain | pain intensity and location | deep pressure pain threshold assessed with a pressure algometer | pre-admission (3 to 8 mos before treatment); before treatment (1 day before); after treatment (day after); 2 mos after beginning of treatment, 5 mos after beginning treatment, 12 mos after beginning treatment
| | | | pain drawing | pre-admission (3 to 8 mos before treatment); before treatment (1 day before); after treatment (day after); 2 mos after beginning of treatment, 5 mos after beginning treatment, 12 mos after beginning treatment
| | | | VAS | pre-admission (3 to 8 mos before treatment); before treatment (1 day before); after treatment (day after); 2 mos after beginning of treatment, 5 mos after beginning treatment, 12 mos after beginning treatment
Kidner 2009 ^166^ | 0 | Emotional Functioning | psychological variables | BDI | 1-yr f/u
| | | | MVAS | 1-yr f/u
| | | | ODI | 1-yr f/u
| | | | quantified pain drawing | 1-yr f/u
| | | | SF-36 | 1-yr f/u
| | Litigation and claims | Work-Comp case settlement | (blank) | 1-yr f/u
| | Pharmacoeconomic/healthcare use | New surgery | (blank) | 1-yr f/u
| | | Seeking treatment from new provider | (blank) | 1-yr f/u
| | Role functioning | Post-rehab SSDI or SSI | yes/no | 1-yr f/u
| | | work retention | was working | 1-yr f/u
| | | work return | had returned to work | 1-yr f/u
| | Symptoms and adverse events | recurrent injury | (blank) | 1-yr f/u
Gatchel 2009 ^90^ | treatment vs. control only | Emotional Functioning | psychosocial measures | BDI | pre-treatment, post-treatment (all participants); 6-mo for n=45 so far
| | | | Fear Avoidance Beliefs Questionnaire | pre-treatment, post-treatment (all participants); 6-mo for n=45 so far
| | Emotional Functioning \| Physical Functioning | psychosocial measures | MPI (Interference, affective distress scales) | pre-treatment, post-treatment (all participants); 6-mo for n=45 so far
| | | | SF-36 | pre-treatment, post-treatment (all participants); 6-mo for n=45 so far
| | Pain | psychosocial measures | Pain VAS | pre-treatment, post-treatment (all participants); 6-mo for n=45 so far
| | Pharmacoeconomic/healthcare use | one-year outcomes | met Medical Board; continued seeking medical care; continued taking pain meds; new surgical procedures for Pain; total no of MD and/or ER visits for pain; total no of different health care providers seen for pain; average pain VAS rating | 1 year post-treatment
| | | Socio-economic measures | Healthcare utilization (pain clinic, PT, Primary care, behavioral health); pain med use (narcotics, NSAIDS, muscle relaxants, acetaminophen) | pre-treatment, post-treatment (all participants); 6-mo for n=45 so far, 12-mo for n=24 so far)
| | Physical Functioning | Physical measures | lifting, treadmill, METS, VO2, Lumbar Flexion, Lumbar Extension | pre-treatment, post-treatment (all participants)
| | | psychosocial measures | ODI | pre-treatment, post-treatment (all participants); 6-mo for n=45 so far
| | | | PDQ | pre-treatment, post-treatment (all participants); 6-mo for n=45 so far
| | | | Physical Activity | pre-treatment, post-treatment (all participants); 6-mo for n=45 so far
Gagnon 2009 ^134^ | 0 | Emotional Functioning | psychological profile | Hospital Anxiety Depression scale | intake, discharge, 3-mo f/u, 6-mo f/u, 12-mo f/u
| | Emotional Functioning Physical Functioning | overall quality of life | VAS | intake, discharge, 3-mo f/u, 6-mo f/u, 12-mo f/u
| | Pain | pain intensity | VAS | intake, discharge, 3-mo f/u, 6-mo f/u, 12-mo f/u
| | Physical Functioning | functional status/disability | Dallas Pain Questionnaire | intake, discharge, 3-mo f/u, 6-mo f/u, 12-mo f/u
| | | | Roland-Morris Disability Questionnaire | intake, discharge, 3-mo f/u, 6-mo f/u, 12-mo f/u
| | | Physical capacity | variety (flexibility, muscle endurance, etc.) | intake, discharge, 3-mo f/u, 6-mo f/u, 12-mo f/u
Howard 2009 ^153^ | “presentees” vs. absentees | Litigation and claims | claim settlement | settlement of pt's disability-related compensation claim | 1-yr
| | Pharmacoeconomic/healthcare use | new healthcare provider | % of pts seeking healthcare from a new provider, suggesting dissatisfaction with health status and disability determinations by current treating and referring doctors | 1-yr
| | | New surgery | surgery to the original compensable injured area during the post-treatment year | 1-yr
| | Role functioning | return to work | any period of work during post-treatment year | 1-yr f/u
| | | work retention | actually working within 2 weeks of outcome interview | 1-yr f/u
| | | Work status | full-time/part-time/school/light-duty; change in job demand preinjury to post-treatment | 1-yr f/u
Mangels 2009 ^178^ | none reported | Coping | Coping with pain | German Pain Management Questionnaire (Fragebogen zur Schmerzverarbeitung) | pre-treatment, post-treatment, 1-yr f/u
| | Emotional Functioning | Depression | BDI | pre-treatment, post-treatment, 1-yr f/u
| | | Life satisfaction concerning health | German Life Satisfaction Questionnaire (Fragebogen zur Lebenszufriedenheit) | pre-treatment, post-treatment, 1-yr f/u
| | | Self-efficacy | PSEQ | pre-treatment, post-treatment, 1-yr f/u
| | Pain | Pain perception | Pain perception scale (SES) | pre-treatment, post-treatment, 1-yr f/u
| | Physical Functioning | Disability | PDI | pre-treatment, post-treatment, 1-yr f/u
| | | health-related quality of life/health status | SF-12 | pre-treatment, post-treatment, 1-yr f/u
Gunreben-Stempfle 2009 ^28^ | none reported | Emotional Functioning | depressive symptoms | CES-D | pre-treatment, 22-week f/u
| | Pain | Headache diary for 4 weeks | Headache diary recording: average pain intensity, number of headache days per month, headache hours per day, headache characteristics (pulsating, aggravation by routine physical activity), associated symptoms (nausea, photophobia, etc.), type and days of medication use | pre-treatment, during treatment, post-treatment
| | | Pain Chronicity | Mainz Pain Staging System | pre-treatment, 22-week f/u
| | Physical Functioning | Health-related Quality of Life | SF-36 | pre-treatment, 22-week f/u
Angst 2009 ^21^ | none reported | Coping | Coping Strategies | CSQ | entry, discharge, 6-mo f/u
| | Emotional Functioning | affective health (anxiety and depression) | HADS | entry, discharge, 6-mo f/u
| | Emotional Functioning Physical Functioning | Symptoms and functioning | SF-36 | entry, discharge, 6-mo f/u
| | Pain \| Emotional Functioning | Pain symptoms/disability, activity, behavior, mood, social relationships | WHYMPI | entry, discharge, 6-mo f/u
| | Pharmacoeconomic/healthcare use | Medication | medical records | entry, discharge
Zunin 2009 ^238^ | none reported | Emotional Functioning | psychological functioning | Million Clinical Multiaxial Inventory-III (MCMI-III) | pre-treatment, post-treatment, 1-year follow-up
| | | | Pain Patient Profile (P3) | pre-treatment, post-treatment, 1-year follow-up
| | | | Symptom Checklist-90-Revised (SCL-90-R) | pre-treatment, post-treatment, 1-year follow-up
| | Pharmacoeconomic/healthcare use | Drug Utilization | Amount of Schedule II opiates prescribed | Intake, completion, one year f/u
| | Physical Functioning | Disablement | clinical assessment and self-report | Intake, completion, one year f/u
| | | Quality of Life | Quality of Life Inventory (QOLI) | pre-treatment, post-treatment, 1-year follow-up
Carleton 2010 ^108^ | Extremity pain vs. lower-back pain | Emotional Functioning | Anxiety, Depression | Anxiety Sensitivity Index | intake, mid-treatment, end of treatment
| | | | CES-D | intake, mid-treatment, end of treatment
| | | | Pain Anxiety Symptoms Scale-20 | intake, mid-treatment, end of treatment
| | | pain catastrophizing | PCS | intake, mid-treatment, end of treatment
| | Pain | Pain | VAS | intake, mid-treatment, end of treatment
| | Physical Functioning | Functional ability | Functional Ability Percent Deficit | intake, mid-treatment, end of treatment
| | | Illness-Injury sensitivity | Illness/Injury Sensitivity Index - Revised (ISI-R) | intake, mid-treatment, end of treatment
| | | Perceived disability | Index of Perceived Disability (IPD) | intake, mid-treatment, end of treatment
Law 2009 ^172^ | none | Emotional Functioning | Pain self-efficacy questionnaire | PSEQ | before and after treatment
| | Physical Functioning | measures addressing study objective of muscle extensibility and stretch tolerance | (blank) | (blank)
Hooten 2009 ^151^ | sex, smoking status (current smoker, former smoker, never smoker) | Emotional Functioning | Depression | Center for Epidemiological Studies-Depression Scale (CES-D) | admission, dismissal
| | | pain catastrophizing | Pain Catastrophizing scale (PCS) | admission, dismissal
| | | Pain-related anxiety and fear | Pain Anxiety Symptoms Scale short form (PASS-20) | admission, dismissal
| | Pain | pain severity and affective characteristics | MPI | admission, dismissal
| | Pharmacoeconomic/healthcare use | Medication use | % using opioids, muscle relaxants, NSAIDS, benzodiazepines | admission, dismissal
| | Physical Functioning | physical functioning, health perception, social functioning | SF-36 | admission, dismissal
Vowles 2010 ^230^ | correlations with outcome variables calculated for: Brief Pain Coping Inventory - 2 (BPCI-2) subscales Pain Management and Psychological Flexibility | Emotional Functioning | Depression | British Columbia Major Depression Inventory | pre-treatment, post-treatment, 3-mo f/u
| | | pain-related anxiety | PASS-20 | pre-treatment, post-treatment, 3-mo f/u
| | Pain | Pain | 0-10 numerical scale | pre-treatment, post-treatment, 3-mo f/u
| | Pharmacoeconomic/healthcare use | Medical Visits past 6 mos | self-report | pre-treatment, 3-mo f/u
| | Physical Functioning | Disability | SIP | pre-treatment, post-treatment, 3-mo f/u
| | | physical performance | 10-minute walk; sit-to-stand trial (repetitions | pre-treatment, post-treatment, 3-mo f/u
| | | | sit-to-stand trial (repetitions | pre-treatment, post-treatment, 3-mo f/u
Hazard 2009 ^149^ | satisfaction with progress, goal achievement, clinical indicators | Emotional Functioning | Changes in clinical measures--emotional functioning | fear avoidance | pre- post- treatment
| | Pain | average pain | Iowa pain thermometer | f/u (1-2 years post treatment)
| | | Changes in clinical measures--pain | Pain | pre- post- treatment
| | Participant ratings of global improvement and satisfaction with treatment | Goal achievement | Patient defined importance and achievement for each personal goal | f/u (1-2 years post treatment)
| | | Treatment satisfaction | 6-point Likert scale | f/u (1-2 years post treatment)
| | Physical Functioning | Changes in clinical measures--Physical functioning | disability, lifting, trunk flexibility, treadmill endurance | pre- post- treatment
| | | Physical Function | SF-36 | f/u (1-2 years post treatment)
| | Role functioning | Work status | Current work status, level (full vs. part time), capacity | f/u (1-2 years post treatment)
Verra 2009 ^22^ | MPI cluster groups (dysfunctional, interpersonally distressed, adaptive copers) | Coping | Coping Strategies | CSQ | entry, discharge
| | Emotional Functioning | affective health (anxiety and depression) | HADS | entry, discharge
| | Emotional Functioning \| Physical Functioning | Symptoms and functioning | SF-36 | entry, discharge
| | Pain \| Emotional Functioning | Pain symptoms/disability, activity, behavior, mood, social relationships | WHYMPI | entry, discharge
Demoulin 2010 ^118^ | sex (physical function outcomes only); pain, function, and kinesiophobia reported for control group 4 weeks apart | Emotional Functioning | Fear of movement or reinjury | Tampa Scale for kinesiophobia | beginning of program, half-way through program, end of program
| | Other | pt knowledge of etiopathogenesis, management, and prevention of LBP | written test: 5 true-false questions, 10 multiple choice questions practical test: Movement Behavior Test evaluating practical knowledge of back-sparing technique | beginning of program, half-way through program, end of program
| | Pain | pain intensity | VAS | beginning of program, half-way through program, end of program
| | Physical Functioning | impact of back pain on daily activities | Roland-Morris Low Back Pain and Disability Questionnaire | beginning of program, half-way through program, end of program
| | | Impact of pain on ADLs | Dallas Pain Questionnaire | beginning of program, half-way through program, end of program
| | | physical functioning | trunk strength, range of motion, aerobic capacity, Sorenson test (endurance of trunk extensor muscles) | beginning of program, half-way through program, end of program
Burnham 2010 ^23^ | medical management vs. MPP | Pain | pain intensity | numerical scale 0 to 10 | intake, mid-treatment, end of treatment
| | Physical Functioning | Pain interference in 7 domains: general activity, mood, walking ability, normal work, relations with others, sleep, life enjoyment | Pain Interference Questionnaire | intake, mid-treatment, end of treatment
Perry 2010 ^77^ | treatment vs. control | Emotional Functioning | Acceptance | SCL-CSQ acceptance | assessment (all pts); 6-mo f/u (usual care only); post-treatment, 1-mo f/u, 9-mo f/u (MPP pts only)
| | | Anxiety and depression | HADS (Hospital Anxiety and Depression Scale) | assessment (all pts); 6-mo f/u (usual care only); post-treatment, 1-mo f/u, 9-mo f/u (MPP pts only)
| | | catastrophizing | PRSS Catastrophizing | assessment (all pts); 6-mo f/u (usual care only); post-treatment, 1-mo f/u, 9-mo f/u (MPP pts only)
| | | Self-efficacy | Moorong Self-Efficacy Scale | assessment (all pts); 6-mo f/u (usual care only); post-treatment, 1-mo f/u, 9-mo f/u (MPP pts only)
| | | | PSEQ | assessment (all pts); 6-mo f/u (usual care only); post-treatment, 1-mo f/u, 9-mo f/u (MPP pts only)
| | Emotional Functioning \| Physical Functioning | Mental and physical health | SF-12 MCS, SF-12 PCS | assessment (all pts); 6-mo f/u (usual care only); post-treatment, 1-mo f/u, 9-mo f/u (MPP pts only)
| | Pain | pain intensity | documented by site with usual intensity of pain marked 0 to 10 | assessment (all pts); 6-mo f/u (usual care only); post-treatment, 1-mo f/u, 9-mo f/u (MPP pts only)
| | Physical Functioning | Life interference | MPI Life Interference | assessment (all pts); 6-mo f/u (usual care only); post-treatment, 1-mo f/u, 9-mo f/u (MPP pts only)
Gatchel 2010 ^142^ | SF-36 scores, ODI scores | Pharmacoeconomic/healthcare use | new healthcare provider | % of pts seeking healthcare from a new provider, suggesting dissatisfaction with health status and disability determinations by current treating and referring doctors | 1-yr
| | | Number of healthcare visits to new provider | number of visits in year post treatment | 1-yr f/u
| | Physical Functioning | Health status | SF-36 | pre-treatment, post-treatment
| | | Perceived functional disabilities caused by pain | Owestry Disability Index (ODI) | pre-treatment, post-treatment
| | Role functioning | return to work | any period of work during post-treatment year | 1-yr f/u
| | | work retention | actually working within 2 weeks of outcome interview | 1-yr f/u

Table D-4 Study details

Citation | Study/Center Name | Country | Funding Source for Study | N | Number of Patients Lost to Followup | Setting (in-patient/outpatient)
Alaranta 1994 ^91^ | AKSELI | Finland | N/A | 152 intervention/141 reference group | 2% | inpatient (MPP had additional pre-training period at home)
Altmaier 1992 ^92^ | Low Back Rehabilitation Program, Spine Diagnostic and Treatment Center, Dept of Orthopaedic Surgery, University of Iowa Hospitals and Clinics | USA | National Institute for Handicapped Research | 45 | 2 dropped out (excluded from data) | inpatient
Andary 1997 ^93^ | College of Osteopathic Medicine, Michigan State University | USA | N/A | 12 with TBI, 12 without TBI | 0 | outpatient
Angst 2006 ^18^ | RehaClinic, Bad Zurzach | Switzerland | Zurzach Rehabilitation Foundation SPA | 125 | 100 pts with incomplete data (initial cohort was 225) | inpatient
Angst 2009 ^21^ | RehaClinic, Bad Zurzach | Switzerland | Zurzach Rehabilitation Foundation SPA | 307 | started with 331 pts, 24 dropped out during treatment, 97 dropped out at 6-mo f/u | inpatient
Bailey 2003 ^94^ | Texas Pain Medicine Clinic | USA | NIH | 162 | 19 dropped out of treatment, 41 were not reached for 6-mo f/u, 59 were not reached for 1-yr f/u | outpatient
Bendix 1998 ^95^ | Copenhagen Back Center | Denmark | Danish Rheumatism Association, Nycomed-DAK, AP Møller og Hustrus Fond, Pensam, Assurandørsocietetet, and others (private foundations, etc.) | 238 | 238 randomized, 13 never started treatment, 20 dropped out of treatment, 31 lost at 5-yr f/u (11 dropouts contacted at 5-yr f/u) | outpatient
Bendix 1995 ^81^ | Copenhagen Back Center | Denmark | Danish Rheumatism Association, Nycomed-DAK, AP Møller og Hustrus Fond, Pensam, Assurandørsocietetet, and others (private foundations, etc.) | 132 | 132 randomized, 9 never started treatment, 14 dropped out of treatment, 3 lost at 4-mo f/u (leaving 106 with full data) | outpatient
Bendix 1996 ^43^ | Copenhagen Back Center | Denmark | Danish Rheumatism Association, Nycomed-DAK, AP Møller og Hustrus Fond, Pensam, Assurandørsocietetet, and others (private foundations, etc.) | 106 | of 106 randomized, 2 never started, 7 dropped out of treatment, 3 could not be reached at f/u | outpatient
Bendix 1997 ^79^ | Copenhagen Back Center | Denmark | Danish Rheumatism Association, Nycomed-DAK, AP Møller og Hustrus Fond, Pensam, Assurandørsocietetet, and others (private foundations, etc.) | 132 | 132 randomized, 9 never started treatment, 14 dropped out of treatment, 6 lost at 12-mo f/u (leaving 103 with full data) | outpatient
Bendix 1998 ^96^ | Copenhagen Back Center | Denmark | Danish Ministry of Health, National Health Fund of Research and Development, Foundation of Director E. Danielsen and wife | 816 | complicated | outpatient
Bendix 1998 ^97^ | Copenhagen Back Center | Denmark | Danish Rheumatism Association, Nycomed-DAK, AP Møller og Hustrus Fond, Pensam, Assurandørsocietetet, and others (private foundations, etc.) | 238 | 238 randomized, 13 never started treatment, 20 dropped out of treatment, 14 lost at 2-yr f/u (6 dropouts contacted at 2-yr f/u) | outpatient
Bendix 2000 ^78^ | Copenhagen Back Center | Denmark | Danish Rheumatism Association, Insurance Company for Industrial Injuries, the DANICA Pension, the Municipal Pension Insurance Company Ltd., and others (private foundations, etc.) | 138 | of 138 randomized, 11 never started, 21 dropped out during treatment, 7 lost at 12-mo f/u | outpatient
Bliokas 2007 ^98^ | Illawarra Pain Management Service, Port Kembla Hospital, Warrawong, NSW | Australia | NSW Motor Accidents Authority research grant | 143 | 49 | outpatient
Buchner 2006 ^99^ | University of Heidelberg | Germany | none reported | 365 | N/A (used only treatment completers with full data) | inpatient
Buchner 2007 ^100^ | University of Heidelberg | Germany | none reported | 405 | 20 pts discharged, discontinued voluntarily during the follow-up period or were not avail for final outcome analysis, leaving 405 | inpatient
Buchner 2007 ^101^ | University of Heidelberg | Germany | None | 387 | 20 pts discharged, discontinued voluntarily during the follow-up period or were not avail for final outcome analysis, leaving 387 | inpatients
Burnham 2010 ^23^ | Central Alberta Pain and Rehabilitation Institute (CAPRI) | Canada | none reported | 29 MPP, 53 supervised medication management | 4 MPP pts left program | outpatient
Burns 2000 ^102^ | Center for Rehabilitation, Lake Forest Hospital | USA | not reported | 93 | 11 pts dropped out of treatment, 11 had incomplete functional capacity measures due to physical restrictions, 8 did not complete MMPI-2 (initial cohort was 123) | outpatient
Burns 1998 ^103^ | Center for Rehabilitation, Lake Forest Hospital | USA | partial NIH | 101 | 11 pts dropped out of treatment, 11 had incomplete functional capacity measures due to physical restrictions (initial cohort was 123) | outpatient
Burns 1998 ^104^ | Center for Rehabilitation, Lake Forest Hospital | USA | partial NIH | 94 | N/A (used only treatment completers | outpatient
Burns 2003 ^105^ | Pain & Rehabilitation Clinic of Chicago (PRCC) and Rehabilitation Institute of Chicago (RIC) | USA | not reported | 65 | ? | outpatient
Burns 2003 ^106^ | Pain & Rehabilitation Clinic of Chicago (PRCC) and Rehabilitation Institute of Chicago (RIC) | USA | none reported | 90 | ? | outpatient
Burns 2005 ^107^ | Pain & Rehabilitation Clinic of Chicago (PRCC) and Rehabilitation Institute of Chicago (RIC) | USA | not reported | 65 | ? | outpatient
Carleton 2010 ^108^ | University of Regina | Canada | CIHR | 51 | not reported | outpatient
Cassisi 1989 ^109^ | University of Miami Comprehensive Pain and Rehabilitation Center (UMCPRC) | USA | none reported | 236 | 39% | inpatient
Cedraschi 2004 ^16^ | Geneva University Hospital | Switzerland | Swiss National Foundation for Research | 164 | 35 | outpatient
Chapman 1990 ^110^ | Emory Pain Control Center | USA | none reported | 160 | 0 | inpatient and outpatient
Chapman 1994 ^111^ | Emory Pain Control Center* | USA | none reported | 122 | 0--included only pts who completed treatment and provided follow-up data | inpatient and outpatient
Chapman 1996 ^112^ | Multiple-USA | USA | none reported | 216 | approx 42 pts did not complete 3-6 mo f/u data | outpatient
Chapman 2000 ^50^ | Multiple-USA | USA | none reported | 309 | 15% dropout rate at Center A, 12% dropout rate at Centers B and C; 32 completers at Center A and 32 completers at Center B did not provide 3-6 mo f/u, Center C did not have any f/u data (only pre-post) | 2 outpatient, one inpatient (Center C)
Ciechanowski 2003 ^113^ | University of Washington Multidisciplinary Pain Center | USA | NIH-NINDS grant | 111 | 29 pts refused survey | outpatient
Connally 1991 ^114^ | Pain Control and Rehabilitation Institute of Georgia | USA | none reported | 17 | 3 withdrew from treatment | inpatient and outpatient
Cott 1990 ^115^ | Behavioural Medicine Unit, St. Joseph's Hospital, McMaster University | Canada | one author supported by NHRDP | 261 | 7 withdrew from treatment | outpatient
Crisostomo 2008 ^116^ | Mayo Clinic: Pain Management Center/Comprehensive Pain Rehabilitation Center | USA | no institutional or industry funds | 383 | dismissal questionnaires completed by 81% of study pts | outpatient
Currie 2003 ^15^ | Addiction Centre, Foothills Medical Centre, Alberta | Canada | none reported | 44 | 28% at 3-moth f/u, 32% at 12-month f/u | outpatient
Davis 1992 ^117^ | AMI Brookwood Pain and Rehabilitation Center, Birmingham, AL | USA | no commercial funding | 46 | 0 | inpatient
Deardorff 1991 ^73^ | Pain Center, Valley Presbyterian Hospital, Van Nuys, CA | USA | not reported | 42 treated, 15 not treated | of 55 pts who treatment, 7 dropped out, 6 were located at f/u; of 23 non-treated, 5 could not be located 3 refused participation | inpatient and outpatient (17 outpatient only, remainder started inpatient, finished outpatient)
Demoulin 2010 ^118^ | Spinal Rehabilitation Center, University Hospital, Liège | Belgium | none reported | 262: 136 completed treatment, 24 control patients (scheduled for treatment) | 126 dropped out of treatment | outpatient
Dersh 2008 ^119^ | PRIDE | USA | partial NIH | 1323 | 123 pts didn't complete treatment and were not followed | outpatient
Doleys 1986 ^120^ | Pain Management Center, Brookwood Medical Center, Birmingham, AL | USA | none reported | 95 | 0; only treatment completers with sufficient data were included | inpatient
Dunstan 2007 ^121^ | Rural NSW | Australia | none reported | 30 | 0 | outpatient
Dysvik 2004 ^122^ | Unknown-Norway | Norway | Rogaland Central Hospital, Stavanger University College | 88 | 12 dropped out of treatment, leaving 76 completers | outpatient
Dysvik 2005 ^123^ | Unknown-Norway | Norway | Rogaland Central Hospital, Stavanger University College | 88 | 27 dropped out of treatment, leaving 61 completers | outpatient
Edwards 2003 ^124^ | Unknown-USA | USA | NIH | 171 | ? | not reported
Elkayam 1996 ^125^ | Maccabi Back Center | Israel | none reported | 84 | 17 dropped out of treatment, leaving 67 in treatment group | outpatient
Elkayam 1996 ^126^ | Maccabi Back Center* | Israel | none reported | 73 | not reported | outpatient
Ersek 2008 ^127^ | Geriatric Pain Self-Mgmt | USA | National Institute of Nursing Research, NIH | 256 | 38 | pt's retirement facility
Evans 2001 ^128^ | PRIDE | USA | partial NIH | 395 | none--only pts with f/u data were included | outpatient
Feuerstein 1993 ^129^ | Center for Occupational Rehabilitation at the University of Rochester Medical Center | USA | National Institute on Disability and Rehabilitation Research and an NIOSH grant | 19 MPP, 15 usual care | ? | outpatient
Fishbain 2005 ^130^ | The Rosamoff Pain Center, South Shore Hospital, Miami Beach, FL | USA | not reported | 118 | 0 | combo ("usually 15 days as inpatients and 15 days as outpatients"
Flavell 1996 ^131^ | Chronic Back Pain Programme, Royal Melbourne Hospital | Australia | Victorian WorkCover Authority | 138 | 55 pts had 3-mo f/u data | outpatient
France 1991 ^132^ | Duke University Medical Center* | USA | not reported | 28 | not reported | inpatient
Fricton 1996 ^133^ | TMJ and Craniofacial Pain Clinic, University of Minnesota | USA | not reported | 94 | Of 138 TMJ pts seen over one year, 20% either not contacted or did not return for reevaluation 1yr later; of 111 seen at follow-up, 76% completed all post-treatment instruments and were included in the study | outpatient
Gagnon 2009 ^134^ | Renodos | none reported | 496 responded at 3-mo f/u, 292 responded at 6-mo f/u, 97 responded at 12-mo f/u | France | inpatient or outpatient | 12-13% had prior lumbar spine surgery; 27-28% were working at the beginning of treatment; 12-14% reported engaging in sport and physical activity
Garcy 1996 ^135^ | PRIDE | USA | One author supported by a grant from NIMH | 1204 | Total cohort size of 1301; follow-up info unavailable for 97 | outpatient
Gatchel 1986 ^136^ | PRIDE | USA | not reported | 134 | not reported | outpatient
Gatchel 1986 ^137^ | PRIDE | USA | not reported | 134 | not reported | outpatient
Gatchel 1994 ^138^ | PRIDE | USA | not reported | 152 | none--only pts with f/u data were included | outpatient
Gatchel 1999 ^139^ | PRIDE* | USA | partial NIMH | 146 | 18 did not complete treatment, 1-yr f/u socioeconomic data IS available and included for those non-completers | outpatient
Gatchel 2002 ^140^ | Eugene McDermott Center for Pain Management, University of Texas Southwestern Medical Center at Dallas | USA | NIH and Sid Richardson Foundation | 65 | N/A | outpatient
Gatchel 2005 ^141^ | PRIDE* | USA | NIH and DOD | 1679 | differs by outcome measure (n reported for outcomes ranges from 482 to 1256; most are 1100 to 1200) | outpatient
Gatchel 2009 ^90^ | Wilford Hall Medical Center and Brooke Army Medical Center | USA | NIH and Congressionally Directed Medical Research Program's Peer Review Medical Research Program | 30 MPP, 36 standard treatment | 0 (preliminary results here--not all follow-up data has been collected for all patients because it was not yet 6 or 12 months from their treatment date) | not reported
Gatchel 2010 ^142^ | PRIDE* | USA | not specified | 1180 | pre- and post-rehab data avail for ∼970 pts; 1-yr f/u available for ∼830 pts | outpatient
Glenn 2003 ^143^ | Pain & Rehabilitation Clinic of Chicago (PRCC) and Rehabilitation Institute of Chicago (RIC) | USA | not reported | 65 | ? | outpatient
Gross 2005 ^144^ | Workers' Compensation Board-Alberta | Canada | Federal and Foundation funds | 438 | some missing data for 26% of subjects | not reported
Guck 1988 ^145^ | Nebraska Pain Management Center (NPMC)/University of Nebraska | USA | not reported | 635 | ? | inpatient
Guck 1999 ^80^ | Nebraska Pain Management Center (NPMC)/University of Nebraska | USA | no commercial funding | 123 | 207 pts completed program; 135 were interviewed at 6-mo f/u; 123 provided data relevant to this study | outpatient
Gunreben-Stempfle 2009 ^28^ | University of Erlangen-Nuremberg | Germany | none reported | 42 in 96-hr treatment cohort, 46 pts in 20-hr treatment cohort, 80 pts receiving primary care alone | 5 of the 42 | outpatient
Gustafsson 2002 ^13^ | Hospital for Rheumatology and Rehabilitation in Östersund | Sweden | Reumatikerföbundet, Center for Studies in Health and Quality of Life, Mid Sweden University, Swedish Medical Research Council, Department of Rehabilitation Medicine at Karolinska Hospital | 43 (23 treatment, 20 waiting-list control) | of 44 patients who began treatment, 1 withdrew from treatment, 2 were not available at assessments 2 and 3, 6 were not available at assessment 4 | outpatient
Hatten 2006 ^146^ | Eugene McDermott Center for Pain Management, University of Texas Southwestern Medical Center at Dallas | USA | partial NIH and DOD | 121 (completed MPP w/o supplemental procedures = 59; completed MPP with supplemental procedures = 22; meds mgmt only = 16; meds mgmt plus supplemental procedures = 24) | N/A | outpatient
Hazard 1989 ^147^ | New England Back Center | USA | None noted | 90, including 59 completers, 5 dropouts, 17 denied insurance authorization, 6 crossovers | ? | outpatient
Hazard 1991 ^148^ | New England Back Center | USA | Danish Research Academy and Sygekassernes Helsefond, Denmark | 258 | 23% to 30% depending on cohort | outpatient
Hazard 2009 ^149^ | Dartmouth-Hitchcock Medical Center's Spine Center | USA | no commercial funding | 106 | 19% | outpatient
Hildebrandt 1997 ^150^ | University of Göttingen | Germany | Federal Ministry of Science and Research | 90 | 8 | outpatient
Hooten 2007 ^19^ | Mayo Clinic: Pain Management Center/Comprehensive Pain Rehabilitation Center | USA | not reported | 159 | 11% did not complete program | outpatient
Hooten 2009 ^151^ | Mayo Clinic: Pain Management Center/Comprehensive Pain Rehabilitation Center | USA | no institutional or corporate funds | 1241 | ∼15% did not complete program | outpatient
Hooten 2009 ^152^ | Mayo Clinic: Pain Management Center/Comprehensive Pain Rehabilitation Center | USA | no institutional or corporate funds | 1241 | ∼15% did not complete program | outpatient
Howard 2009 ^153^ | PRIDE* | USA | not reported | 2191 | no outcome data for 750 non-completers | outpatient
Huge 2006 ^154^ | Munich Functional Restoration Program | Germany | none reported | 44 | 0 | outpatient
Jensen 1995 ^155^ | Unknown-Sweden* | Sweden | Board for Research in Health and Care in the Northern region of Sweden, Folksam research | 66 | 4 | inpatient
Jensen 1994 ^156^ | NärRehab/Hälsoinvest, Örebro | Sweden | AMF, Trygghetsförsäkringar | 70: 35 treatment, 35 control | 4 | outpatient
Jensen 1998 ^157^ | NärRehab/Hälsoinvest, Örebro | Sweden | AMF, Trygghetsförsäkringar | 96 (67 treatment, 29 control) | 13 (initial cohort size was 76 treatment and 35 control) | outpatient
Jensen 1992 ^158^ | University of Washington Multidisciplinary Pain Center | USA | partial AHCPR funding; partial National Research Service Award; partial Graduate School Research Fund (UW) | 144 | 116 enrolled for treatment of 144 screened; 3- mo f/u completed by 52 pts | inpatient
Jensen 1994 ^159^ | University of Washington Multidisciplinary Pain Center | USA | partial National Research Service Award; partial Graduate School Research Fund (UW) | 94 | 47 pts began study but didn't provide 3 to 6 mo f/u data (not included in the N = 94 figure) | inpatient
Jensen 2001 ^160^ | University of Washington Multidisciplinary Pain Center | USA | NIH | 197 | 28% | outpatient
Jensen 2003 ^14^ | University of Washington Multidisciplinary Pain Center and St. Joseph's Health Care Arthritis Institute multidisciplinary fibromyalgia program (London, Ontario) | US and Canada | Partial NIH | 144 Washington (UW), 99 Fibromyalgia (FM) | 31 UW, 18 FM | outpatient
Jensen 2004 ^17^ | University of Washington Multidisciplinary Pain Center and St. Joseph's Health Care Arthritis Institute multidisciplinary fibromyalgia program (London, Ontario) | US and Canada | Partial NIH | 110 Washington, 319 Fibromyalgia | 32 UW, 102 FM | outpatient
Jensen 2007 ^161^ | University of Washington Multidisciplinary Pain Center | USA | NIH support for data collection | 141 | N/A (used only treatment completers with full data) | outpatient
Jousset 2004 ^162^ | Multiple-France | France | Union Régionale des Caisses d'Assurance Maladie des Pays de Loire | 86 | 3 total (2 didn't start the program, 1 lost at 6 mo f/u) | outpatient
Kaapa 2006 ^163^ | Finnish Back Institute, Helsinki | Finland | foundation funds; no commercial benefits | 120 | 5 lost at 6-mo f/u, 8 more lost at 12-mo f/u, 12 more lost at 24 mo f/u | outpatient
Kenny 2004 ^164^ | Royal North Shore Hospital, Sydney: ADAPT/SpinalADAPT | Australia | None noted | 77 | not reported | outpatient
Keogh 2005 ^165^ | Royal National Hospital for Rheumatic Diseases, Bath | UK | none reported | 98 | 143 pts initially recruited, 13 withdrew from treatment, 32 did not attend f/u appt | residential or inpatient-hospital
Kidner 2009 ^166^ | PRIDE | USA | partial NIH | 1226 | 272 | outpatient
Kleinke 1988 ^167^ | Spaulding Rehabilitation Hospital, Boston | USA | none reported | 60 | N/A (used only treatment completers | inpatient
Kohles 1990 ^168^ | PRIDE | USA | none reported | 45 from first year of program, 57 from a later year | N/A (used only treatment completers | outpatient
Kole-Snijders 1999 ^169^ | Hoensbroeck Rehabilitation Center | Netherlands | Investigative Medicine Fund of the Dutch Insurance Council | 148 | 19 dropped out during treatment, 16 lost during follow-up, 5 lost during waiting periods for a total of 40 lost out of 148 | inpatient and outpatient
Koopman 2004 ^170^ | Rehabilitation Center Heliomare | Netherlands | none reported | 51 | 17 (initial cohort was 68) | outpatient
Lang 2003 ^171^ | University of Erlangen-Nuremberg | Germany | German Federal Ministry of Health | 51 MPP pts, 157 comparison usual care patients | 5 of 56 patients who began the MPP dropped out before the fifth session | outpatient
Law 2009 ^172^ | Royal North Shore Hospital, Sydney: ADAPT/SpinalADAPT | Australia | none reported | 30 | 0 | outpatient
Lipchik 1993 ^48^ | Cleveland Clinic Pain Management Unit | USA | not reported | 50 inpatient and 46 comparison from an outpatient program | 3 pts from comparison group (initial cohort of 49), 1 pt from treatment group (initial cohort of 50) | inpatient (compared to an outpatient program)
Luoto 1996 ^173^ | AKSELI | Finland | Finnish Work Environment Fund | 99 low-back pain pts, 61 healthy controls | 4% | inpatient
Luoto 1998 ^174^ | AKSELI | Finland | Finnish Work Environment Fund | 99 low-back pain pts, 61 healthy controls | 4% | inpatient
Lynch 1996 ^175^ | University Hospital Rehabilitation Center at University of Wisconsin-Madison* | USA | Wisconsin Alumni Research Foundation | 64 (30 program completers, 34 who never entered or never completed the program) | 14 of 30 completers and 12 of 34 non-completers returned follow-up questionnaire | outpatient
Maclaren 2006 ^176^ | Oasis Occupational Rehabilitation and Pain Management, Morgantown, WV* | USA | none reported | 127 completers | ∼24% of treatment starters dropped out of treatment; of completers, 18 did not have return-to-work data, leaving 127 pts in study | outpatient
Magnusson 2004 ^27^ | Calgary Chronic Pain Centre | Canada | two authors received funding for training from GlaxoSmithKline | 52 MPP, 75 pharmacological | 5 pharma, 16 MPP (analysis done on 70 pharma, 36 MPP) | outpatient
Man 2007 ^177^ | Comprehensive Outpatient Pain Engagement, Alice Ho Miu Ling Nethersole Hospital | Hong Kong | none reported | 49 | 4 withdrew from treatment | outpatient
Mangels 2009 ^178^ | Rehazentrum Bad Pyrmont Klinik Weser | Germany | Deutsche Rentenversicherung Bund (German Annuity Insurance Association) | 363 | 6% | inpatient
Maruta 1990 ^179^ | Mayo Clinic: Pain Management Center/Comprehensive Pain Rehabilitation Center | USA | none reported | 249 | 13% | inpatient
Masuda 2005 ^40^ | Hattanmaru Hospital | Japan | none reported | 46 | 2 | inpatient
Mayer 1994 ^180^ | PRIDE* | USA | none reported | 194 | not reported | outpatient
Mayer 1998 ^75^ | PRIDE* | USA | none reported | 448 | 2%-3% | outpatient
Mayer 2001 ^181^ | PRIDE* | USA | partial NIH | 1052 | ? | outpatient
Mayer 2006 ^182^ | PRIDE | USA | none | 2729 | none (partial available on all--e.g‥, from insurance companies family, etc.); full interview on 93% | outpatient
Mayer 1986 ^183^ | PRIDE | USA | none reported | 73 started, 66 completed PRIDE program; comparison group of 74 pts from a nearby "traditional multidisciplinary program" | 12 not retested for functional capacity | outpatient
Mayer 1987 ^184^ | PRIDE | USA | none reported | 116 treatment completers, 72 comparison group (denied entry by insurance carrier), 11 treatment non-completers | physical testing completed at 3- and 6-mo on 81 and 56 pts only; no info on interview completion at 1 and 2 yr f/u | outpatient
Mayer 1988 ^185^ | PRIDE | USA | none reported | 100 | none reported | outpatient
Mayer 2002 ^186^ | PRIDE* | USA | no commercial funding | 202 (52 surgical, 150 comparison) | 5-7% have incomplete data, some f/u data available on all pts in study | outpatient
Mayer 2008 ^187^ | PRIDE* | USA | none | 2730 | 365 dropped out of treatment; partial info available on them | outpatient
McCracken 2005 ^188^ | Royal National Hospital for Rheumatic Diseases, Bath | UK | NHS Trust at hospital; West Virginia University | 108 | 13 withdrew from treatment, 21 were missing baseline, pre, or post data; 24 were missing 3-mo f/u data (leaving 108 with 3 out of data points and 84 with complete data) | residential or inpatient-hospital
Michaelson 2004 ^189^ | Saxnäsgårdens Rehabilitation Center | Sweden | VINNOVA | 315 | 12 dropped out of treatment, 68 unavailable at 12-mo f/u | inpatient
Middaugh 1988 ^190^ | Medical University of South Carolina, Charleston* | USA | partial NIH, partial Med U SC | 37 | 2 pts (2 older pts not reached at 6 or 12 months; younger cohort was 20 consecutive pts with 1-yr follow-up available) | inpatient or outpatient
Mohler 1991 ^191^ | Cardinal Hill Hospital, Lexington KY* | USA | none reported | 17 | of original 25, 2 withdrew from treatment and 6 were unavailable for follow-up | outpatient
Moore 1986 ^24^ | Harry S Truman Memorial Veterans Hospital* | USA | none reported | 57 | 0 | inpatient
Norrefalk 2005 ^192^ | Pain Unit, Department of Rehabilitation Medicine, Huddinge University Hospital | Sweden | None reported | 72 enrolled in program, 14 pts rejected due to lack of space | 5 dropped out of treatment | outpatient
Norrefalk 2006 ^193^ | Pain Unit, Department of Rehabilitation Medicine, Huddinge University Hospital | Sweden | none reported | 67 | all pts had at least partial f/u data | outpatient
Norrefalk 2007 ^194^ | Pain Unit, Department of Rehabilitation Medicine, Huddinge University Hospital | Sweden | N/A | 149 intervention / 79 control | 27 | outpatient
Norrefalk 2008 ^195^ | Pain Unit, Department of Rehabilitation Medicine, Huddinge University Hospital | Sweden | none reported | 67 treated plus 67 matched comparison group | all pts had at least partial f/u data | outpatient
Olason 2004 ^196^ | Reykjalaundur Rehabilitation Center | Iceland | none reported | 158 | not reported | inpatient
Patrick 2004 ^197^ | Low Back Rehabilitation Program, Spine Diagnostic and Treatment Center, Dept of Orthopaedic Surgery, University of Iowa Hospitals and Clinics | USA | U of Iowa, no commercial funding | 45 | 19 | inpatient
Perry 2010 ^77^ | Royal North Shore Hospital, Sydney: ADAPT/SpinalADAPT | Australia | none reported | 36 | 6 total (all from treatment arm: 1 withdrew from treatment, 1 withdrew from f/u at 1-m, 4 unavailable/unable to complete at 9 mo. f/u) | outpatient
Pfingsten 1997 ^74^ | University of Göttingen* | Germany | German Ministry of Education, Research and Technology | 90 | 3 pts not reached at 12-mo f/u | outpatient
Polatin 1989 ^198^ | PRIDE | USA | none reported | 326 | N/A (looked at pre-treatment variables for different groups) | outpatient
Polatin 1997 ^199^ | PRIDE* | USA | partial NIH | 50 | N/A (used only treatment completers | outpatient
Proctor 2004 ^200^ | PRIDE | USA | partial NIH | 1316 | all pts had at least partial f/u data | outpatient
Proctor 2005 ^201^ | PRIDE* | USA | partial NIH | 1440 | 6% of completers and 15% of non-completers had no 1-yr f/u data; all others had at least partial data | outpatient
Protas 2004 ^202^ | PRIDE* | USA | partial NIH | 683 | not reported | outpatient
Rainville 1992 ^203^ | Unknown-USA | USA | none noted | 40 | 0 | outpatient
Rainville 1993 ^204^ | Unknown-USA | USA | None noted | 72 | 20 pts did not enroll, 10 pts initiated treatment but dropped out (these 30 are the comparison group) | outpatient
Robbins 2003 ^38^ | Eugene McDermott Center for Pain Management, University of Texas Southwestern Medical Center at Dallas | USA | partial NIH and Sid Richardson Foundation | 127 completers | 62 | outpatient (?) not specified
Rome 2004 ^205^ | Mayo Clinic: Pain Management Center/Comprehensive Pain Rehabilitation Center | USA | not reported | 356 | 14% dropped out of treatment, further 8.7% completed treatment but didn't complete pre-post questionnaires | outpatient
Sanders 1993 ^26^ | Pain Control and Rehabilitation Institute of Georgia | USA | none reported | 180 | 13% dropped out of treatment; of completers, 120 randomly selected for follow-up assessment, of which 90 completed follow-up assessment | outpatient
Scerri 2006 ^206^ | Unknown-Switzerland | Switzerland | none reported | 88 | 0 | not reported, assumed outpatient based on hours of treatment per week
Scharff 1994 ^25^ | Pain Evaluation and Treatment Institute, University of Pittsburgh Medical Center | USA | grant from Raymond and Elizabeth Bloch Educational and Charitable Foundation | 35 treated patients, 31 decliners | 3 treatment dropouts, 8 treatment decliners | outpatient
Skinner 1990 ^207^ | Whittington Hospital | UK | NE Thames Regional Health Authority | 39 | 5 | outpatient
Skouen 2002 ^208^ | Bergen/Haukeland University | Norway | Royal Norwegian Ministry of Health and Social Affairs | 195 | 3 dropped out of treatment, several were government workers (no return-to-work data available) | outpatient
Skouen 2006 ^29^ | Bergen/Haukeland University | Norway | Royal Norwegian Ministry of Health and Social Affairs | 219 | 4 dropped out of treatment, 7 were government workers with no return-to-work data (leaving 208 with f/u) | outpatient
Snow 1988 ^209^ | Orthopaedic Arthritis Pain Center at the Hospital for Joint Diseases Orthopaedic Institute | USA | none reported | 200 | 38% | inpatient and outpatient
Snow 1990 ^210^ | Orthopaedic Arthritis Pain Center at the Hospital for Joint Diseases Orthopaedic Institute | USA | none | 1 | N/A | inpatient and outpatient
Spinhoven 2004 ^211^ | Hoensbroeck Rehabilitation Center | Netherlands | none reported | 148 | 19 dropped out during treatment, 16 lost during follow-up, 5 lost during waiting periods for a total of 40 lost out of 148 | inpatient and outpatient
Stans 1989 ^212^ | Louvain Pain Clinic | Belgium | none reported | 35 | 11 | inpatient and outpatient
Sterner 2001 ^213^ | University Hospital of Northern Sweden, Umeå, and University Hospital, Linköping | Sweden | Swedish National Board of Health and Welfare | 88 | 24 | outpatient
Storro 2004 ^214^ | Clinic of Physical Medicine 3T | Norway | partial support from Norwegian Research Council | 121 treatment/97 control | None; however, 5 intervention pts dropped out of the intervention program (follow-up info still collected), one dropped out due to improved condition and returned to work | outpatient
Suman 2009 ^20^ | Siena University* | Italy | Ministero dell'Istruzione, dell'Università e della Ricerca, Rome, Italy, and PAR (University of Siena) | 25 | 0 | residential (hotel near hospital for weekdays, home on weekends)
Suoyrjo 2008 ^215^ | Finnish Ten-Town Study | Finland | Social Insurance Institution of Finland, Academy of Finland, Finnish Work Environment Fund, participating towns | 613 rehab participants compared to 34,000 non-rehab participants | some pts were followed for 10 years (250 back pain, 133 neck pain, 23,379 non-rehab) | inpatient
Tollison 1985 ^216^ | Pain Therapy Center, Greenville, SC | USA | none reported | 100 | 17 | inpatient
Tollison 1989 ^217^ | Pain Therapy Center, Greenville, SC | USA | none reported | 30 | 5 | inpatient
Tollison 1990 ^218^ | Pain Therapy Center, Greenville, SC | USA | none noted | 30 | 1 | inpatient
Trief 1995 ^219^ | SUNY Syracuse | USA | none noted | 48 | ? | outpatient
Turk 1998 ^12^ | Pain Evaluation and Treatment Institute, University of Pittsburgh Medical Center* | USA | partial Arthritis Foundation -- Western PA chapter | 70 | 8% didn't complete treatment; of 70 who did, 3 had incomplete data and were excluded from analysis; at six-month follow-up, 38 completed questionnaires | outpatient
Turner-Stokes 2003 ^76^ | COPE program, London | UK | Medical Research Council and Luff Foundation | 126 randomized, 66 completed group therapy, 47 completed individual therapy | 13 dropped out during treatment, 29 did not attend 1-yr f/u (data available for 84) | outpatient
van Wilgen 2009 ^220^ | University Medical Centre Groningen | Netherlands | none reported | 32 | 6 | inpatient
Vendrig 1999 ^221^ | Rug AdviesCentra Nederland | Netherlands | none reported | 143 | 4 | outpatient
Vendrig 2000 ^222^ | Rug AdviesCentra Nederland | Netherlands | N/A | 120 | Not given; 2 pts excluded for invalid MMPI validity scores | outpatient
Vendrig 2000 ^223^ | Rug AdviesCentra Nederland | Netherlands | none reported | 26 | ? | outpatient
Verra 2009 ^22^ | RehaClinic, Bad Zurzach | Switzerland | Zurzach Rehabilitation Foundation SPA | 118 | ? | inpatient
Vines 1996 ^224^ | Maine Pain Center* | USA | None noted | 23 | ? | outpatient
Vines 2000 ^225^ | Maine Pain Center* | USA | None noted | 23 | ? | outpatient
Vollenbroek-Hutten 2004 ^226^ | Roessingh Back Rehabilitation Programme | Netherlands | None reported | 163 | 10 treatment, 11 control | outpatient
Vowles 2004 ^227^ | Oasis Occupational Rehabilitation and Pain Management, Morgantown, WV* | USA | none reported | 183 | 45 pts did not complete treatment (of the initial 183 treatment starters) | outpatient
Vowles 2007 ^228^ | Royal National Hospital for Rheumatic Diseases, Bath* | UK | none reported | 252 | 24 pts dropped out of treatment; 191 of 252 treatment completers had 3-mo f/u data | residential?
Vowles 2008 ^229^ | Royal National Hospital for Rheumatic Diseases, Bath | UK | none reported | 171 | 16 pts dropped out of treatment; 114 of 171 treatment completers had 3-mo f/u data | residential
Vowles 2010 ^230^ | Royal National Hospital for Rheumatic Diseases, Bath* | UK | none reported | 114 | 16 pts dropped out of treatment; 114 of 171 treatment completers had 3-mo f/u data | residential
Walsh 2002 ^231^ | King's Mill Hospital Back Pain Unit | UK | none reported | 84 | 6% attrition during program, 12% attrition between completion and 3-mo f/u | outpatient
Walsh 2004 ^232^ | King's Mill Hospital Back Pain Unit | UK | N/A (no commercial funding) | 101 | 30 [attrition from program is 4%] | outpatient
Wang 2008 ^47^ | University of Heidelberg | Germany | none reported | 120 pain patients matched to 120 health controls | ? | inpatient
Wasan 2004 ^233^ | Chronic Pain Treatment Service, Johns Hopkins Hospital Department of Psychiatry and Behavioral Sciences | USA | lead author is a Pfizer postdoctoral fellow in pain medicine | 25 pts MPP + ECT, 25 matched pts MPP only | 3 ECT patients were not matched | inpatients
Williams 1993 ^234^ | INPUT, St. Thomas' Hospital, London | UK | INPUT unit funding from Kind Edward's Hospital Fund for London, regional health authority, etc. | 212 | of 243 inpatients, 23 dropped out, 3 discharged early, 5 gave incomplete data due to language/literacy leaving before/after data for 212; of these, 15 were missing 1-mo f/u; 118 pts had 6 mo f/u data | inpatient
Williams 1999 ^49^ | INPUT, St. Thomas' Hospital, London | UK | INPUT unit funding from Kind Edward's Hospital Fund for London, regional health authority, etc. | 121 randomized; compared with 128 who didn't agree to randomization; waiting list control of 30 (out of the 121 randomized) | 11 (all treatment condition) lost b/w assignment and admission; 38 did not complete 1-mo f/u; 90 did not complete 12-mo f/u | both
Wong 2009 ^235^ | Cannock Chase Hospital | UK | none reported | 70 | 93 of 163 completers | outpatient
Wormgoor 2008 ^236^ | Kysthospital, Vestfold (now called Hospital for Rehabilitation -- Stavern, Rikshospitalet Medical Centre) | Norway | none reported | 94 | 24 of 118 were not available at 6-mo f/u | inpatient
Wright 1999 ^237^ | PRIDE* | USA | none reported | 1198 (421 with cervical spine disorders, 777 with lumbar spine disorders) | 119 did not complete treatment: only pre-treatment data available; for completers, 98% have at least partial follow-up data | outpatient
Zunin 2009 ^238^ | Integrative Healthcare Group & Rehabilitative Center, Honolulu | USA | HMSA and ZEIR | 35 | ? | outpatient

Table D-5 Study designs

Citation | Study Testing | Comparison Treatment? (MPP, non-MPP, False) | Comparison Treatment Assigned Randomly? | Comparison group? (as a design feature) | Prospective or Retrospective
Alaranta 1994 ^91^ | treatment | Non-MPP | FALSE | FALSE | prospective
Altmaier 1992 ^92^ | treatment | Non-MPP | TRUE | FALSE | prospective
Andary 1997 ^93^ | patient characteristics: predictive | N/A | N/A | comorbidity | Retrospective
Angst 2006 ^18^ | treatment | N/A | N/A | diagnosis/pain location | prospective
Angst 2009 ^21^ | treatment | Non-MPP | FALSE | FALSE | prospective
Bailey 2003 ^94^ | predictors | N/A | N/A | patient history | prospective
Bendix 1998 ^95^ | treatment | non-MPP and no treatment | TRUE | FALSE | prospective
Bendix 1995 ^81^ | treatment | Non-MPP | TRUE | FALSE | prospective
Bendix 1996 ^43^ | treatment | No treatment | TRUE | FALSE | prospective
Bendix 1997 ^79^ | treatment | non-MPP | TRUE | FALSE | prospective
Bendix 1998 ^96^ | patient characteristics: predictive | non-MPP and no treatment | FALSE | FALSE | prospective
Bendix 1998 ^97^ | treatment | Non-MPP | TRUE | FALSE | prospective
Bendix 2000 ^78^ | treatment | Non-MPP | TRUE | FALSE | prospective
Bliokas 2007 ^98^ | treatment/treatment component | MPP and waiting list | TRUE | FALSE | prospective
Buchner 2006 ^99^ | treatment | N/A | N/A | diagnosis/pain location | Prospective
Buchner 2007 ^100^ | patient characteristics: predictive | N/A | N/A | age | Prospective
Buchner 2007 ^101^ | patient characteristics: predictive | N/A | N/A | chronicity | prospective
Burnham 2010 ^23^ | treatment | N/A | N/A | FALSE | prospective
Burns 2000 ^102^ | predictors | N/A | N/A | cognitive/psychological | secondary analysis
Burns 1998 ^103^ | predictors | N/A | N/A | cognitive/psychological and sex | secondary analysis
Burns 1998 ^104^ | predictors | N/A | N/A | cognitive/psychological and physical | secondary analysis
Burns 2003 ^105^ | intervention mechanisms (cognitive) | N/A | N/A | cognitive/psychological | secondary analysis
Burns 2003 ^106^ | intervention mechanisms (cognitive) | N/A | N/A | cognitive/psychological | secondary analysis
Burns 2005 ^107^ | intervention mechanisms (cognitive) | N/A | N/A | cognitive/psychological | secondary analysis
Carleton 2010 ^108^ | patient characteristics: predictive | N/A | N/A | diagnosis/pain location | Retrospective
Cassisi 1989 ^109^ | treatment | usual care | FALSE | FALSE | retrospective?
Cedraschi 2004 ^16^ | treatment | waiting list | TRUE | FALSE | prospective
Chapman 1990 ^110^ | patient characteristics | N/A | N/A | cognitive/psychological | secondary analysis
Chapman 1994 ^111^ | predictors | N/A | N/A | cognitive/psychological | ?follow-up questionnaire
Chapman 1996 ^112^ | instrument validation | N/A | N/A | FALSE | prospective?
Chapman 2000 ^50^ | cost effectiveness | MPP (some outcomes given by treatment center; treatment details varied somewhat among the centers, though all qualify as MPPs) | FALSE | FALSE | prospective?
Ciechanowski 2003 ^113^ | patient characteristics: predictive | N/A | N/A | cognitive/psychological | secondary analysis
Connally 1991 ^114^ | patient characteristics: predictive | N/A | N/A | cognitive/psychological, behavioral | prospective
Cott 1990 ^115^ | treatment | MPP | FALSE | FALSE | prospective
Crisostomo 2008 ^116^ | treatment component | N/A | N/A | surgical history | retrospective
Currie 2003 ^15^ | treatment | N/A | N/A | FALSE | prospective
Davis 1992 ^117^ | treatment | N/A | N/A | FALSE | prospective
Deardorff 1991 ^73^ | treatment | No treatment | FALSE | FALSE | prospective
Demoulin 2010 ^118^ | treatment | waiting list | unknown | FALSE | prospective
Dersh 2008 ^119^ | predictors | N/A | N/A | comorbidity (opioid dependency) | prospective
Doleys 1986 ^120^ | patient characteristics | N/A | N/A | narcotic use pre-treatment | prospective
Dunstan 2007 ^121^ | treatment | N/A | N/A | FALSE | prospective
Dysvik 2004 ^122^ | treatment | N/A | N/A | FALSE | prospective?
Dysvik 2005 ^123^ | treatment | N/A | N/A | FALSE | prospective?
Edwards 2003 ^124^ | patient characteristics: predictive | N/A | N/A | behavioral, sex | prospective?
Elkayam 1996 ^125^ | treatment | N/A | N/A | FALSE | prospective
Elkayam 1996 ^126^ | measurement validity | N/A | N/A | CT findings | prospective?
Ersek 2008 ^127^ | treatment | Non-MPP | TRUE | FALSE | prospective
Evans 2001 ^128^ | patient characteristics: predictive | N/A | N/A | recurrent injury vs. nonrecurrent injury | prospective
Feuerstein 1993 ^129^ | treatment | usual care | FALSE | FALSE | prospective
Fishbain 2005 ^130^ | treatment | N/A | N/A | FALSE | Data collected prospectively
Flavell 1996 ^131^ | treatment | N/A | N/A | FALSE | retrospective
France 1991 ^132^ | patient characteristics | N/A | N/A | biomedical (CSF levels of Beta-Endorphins) | prospective
Fricton 1996 ^133^ | patient characteristics (psychosocial, demographic): predictive | N/A | N/A | FALSE | prospective
Gagnon 2009 ^134^ | treatment | N/A | N/A | FALSE | 748
Garcy 1996 ^135^ | treatment, prevention/prediction of recurrence | N/A | N/A | FALSE | prospective
Gatchel 1986 ^136^ | instrument validation, patient characteristics | N/A | N/A | FALSE | Data collected prospectively
Gatchel 1986 ^137^ | instrument utility, patient characteristics | N/A | N/A | FALSE | Data collected prospectively
Gatchel 1994 ^138^ | patient characteristics: predictive | N/A | N/A | cognitive/psychological | prospective
Gatchel 1999 ^139^ | patient characteristics: predictive | N/A | N/A | FALSE | “prospectively selected”
Gatchel 2002 ^140^ | instrument utility, patient characteristics | N/A | N/A | FALSE | prospective
Gatchel 2005 ^141^ | patient characteristics | N/A | N/A | sex, social characteristics (marriage, children) | Data collected prospectively
Gatchel 2009 ^90^ | Treatment | usual care | TRUE | FALSE | prospective
Gatchel 2010 ^142^ | measurement validity | N/A | N/A | FALSE | prospective
Glenn 2003 ^143^ | intervention mechanisms (cognitive) | N/A | N/A | FALSE | Data collected prospectively
Gross 2005 ^144^ | Predictors | N/A | N/A | FALSE | retrospective
Guck 1988 ^145^ | patient characteristics: predictive | N/A | N/A | FALSE | Data collected prospectively
Guck 1999 ^80^ | instrument validation | N/A | N/A | FALSE | Data collected prospectively
Gunreben-Stempfle 2009 ^28^ | treatment | non-MPP and no treatment (not concurrent) | FALSE | FALSE | retrospective
Gustafsson 2002 ^13^ | treatment | waiting list | FALSE | FALSE | Prospective
Hatten 2006 ^146^ | cost effectiveness | MPP, non-MPP | FALSE | FALSE | retrospective
Hazard 1989 ^147^ | treatment | No treatment and crossover | FALSE | FALSE | prospective
Hazard 1991 ^148^ | patient characteristics: predictive | N/A | N/A | FALSE | Data collected prospectively
Hazard 2009 ^149^ | measurement validity | N/A | N/A | FALSE | prospective
Hildebrandt 1997 ^150^ | patient characteristics: predictive | N/A | N/A | FALSE | prospective
Hooten 2007 ^19^ | treatment | N/A | N/A | FALSE | prospective
Hooten 2009 ^151^ | predictors | N/A | N/A | sex, smoking | retrospective
Hooten 2009 ^152^ | predictors | N/A | N/A | smoking | retrospective
Howard 2009 ^153^ | patient characteristics | N/A | N/A | behavioral (presenteeism) | Data collected prospectively
Huge 2006 ^154^ | treatment | assessment, no treatment | FALSE | matched controls | retrospective
Jensen 1995 ^155^ | treatment component, cost effectiveness | non-MPP | 0 | FALSE | Prospective
Jensen 1994 ^156^ | treatment | No treatment | FALSE | matched controls | prospective
Jensen 1998 ^157^ | treatment | No treatment | FALSE | matched controls | prospective
Jensen 1992 ^158^ | instrument validation | N/A | N/A | FALSE | prospective
Jensen 1994 ^159^ | intervention mechanisms (cognitive) | N/A | N/A | FALSE | prospective
Jensen 2001 ^160^ | intervention mechanisms (cognitive) | N/A | N/A | FALSE | prospective
Jensen 2003 ^14^ | patient characteristics: predictive | MPP (some outcomes given by treatment center; treatment details varied somewhat among the centers, though all qualify as MPPs) | FALSE | cognitive/psychological | prospective
Jensen 2004 ^17^ | patient characteristics: predictive | MPP (some outcomes given by treatment center; treatment details varied somewhat among the centers, though all qualify as MPPs) | FALSE | cognitive/psychological | prospective
Jensen 2007 ^161^ | intervention mechanisms (cognitive) | N/A | N/A | cognitive/psychological | prospective
Jousset 2004 ^162^ | treatment | Non-MPP | TRUE | FALSE | prospective
Kaapa 2006 ^163^ | treatment | Non-MPP | TRUE | FALSE | prospective
Kenny 2004 ^164^ | treatment component | MPP | TRUE | FALSE | prospective
Keogh 2005 ^165^ | patient characteristics: predictive | N/A | N/A | sex | prospective
Kidner 2009 ^166^ | patient characteristics: predictive | N/A | N/A | opioid use pre-treatment | “prospectively assessed”
Kleinke 1988 ^167^ | instrument validation | N/A | N/A | FALSE | prospective
Kohles 1990 ^168^ | treatment | MPP (not concurrent) | FALSE | FALSE | Data collected prospectively
Kole-Snijders 1999 ^169^ | treatment component | MPP, waiting list | TRUE | FALSE | prospective
Koopman 2004 ^170^ | treatment | N/A | N/A | FALSE | Prospective
Lang 2003 ^171^ | treatment | usual care | FALSE | FALSE | prospective
Law 2009 ^172^ | treatment component | MPP | TRUE | FALSE | prospective
Lipchik 1993 ^48^ | treatment, intervention mechanism | non-MPP | FALSE | FALSE | prospective
Luoto 1996 ^173^ | intervention mechanisms (physical) | N/A | N/A | healthy controls | prospective
Luoto 1998 ^174^ | intervention mechanisms (physical) | N/A | N/A | healthy controls | prospective
Lynch 1996 ^175^ | treatment | No treatment and non-completers | FALSE | FALSE | retrospective
Maclaren 2006 ^176^ | patient characteristics: predictive | N/A | N/A | opioid use pre-treatment | prospective
Magnusson 2004 ^27^ | treatment | non-MPP | FALSE | FALSE | prospective
Man 2007 ^177^ | treatment | N/A | N/A | FALSE | prospective
Mangels 2009 ^178^ | treatment | non-MPP | TRUE | FALSE | prospective
Maruta 1990 ^179^ | treatment | N/A | N/A | FALSE | Data collected prospectively
Masuda 2005 ^40^ | treatment component | MPP | 0 | FALSE | prospective
Mayer 1994 ^180^ | patient characteristics: predictive | N/A | N/A | sex, surgical status | Prospective
Mayer 1998 ^75^ | patient characteristics: predictive | MPP | FALSE | surgical history, matched controls | “prospectively evaluated”
Mayer 2001 ^181^ | patient characteristics: predictive | N/A | N/A | age | prospective
Mayer 2006 ^182^ | patient characteristics: predictive | N/A | N/A | obesity | prospective
Mayer 1986 ^183^ | measurement validity | MPP? | FALSE | FALSE | Prospective
Mayer 1987 ^184^ | treatment | No treatment and non-completers | FALSE | FALSE | Prospective
Mayer 1988 ^185^ | measurement validity | N/A | N/A | FALSE | prospective
Mayer 2002 ^186^ | treatment | MPP | 0 | surgical history | prospective
Mayer 2008 ^187^ | patient characteristics | N/A | N/A | comorbidity | prospective
McCracken 2005 ^188^ | treatment | waiting list | FALSE | FALSE | Prospective
Michaelson 2004 ^189^ | patient characteristics: predictive | N/A | N/A | diagnosis/pain location | prospective
Middaugh 1988 ^190^ | patient characteristics: predictive | N/A | N/A | age | prospective
Mohler 1991 ^191^ | treatment | N/A | N/A | FALSE | prospective
Moore 1986 ^24^ | patient characteristics: predictive | N/A | N/A | FALSE | prospective
Norrefalk 2005 ^192^ | patient characteristics: predictive | No treatment | FALSE | FALSE | prospective
Norrefalk 2006 ^193^ | patient characteristics: predictive | N/A | N/A | ethnicity | Data collected prospectively
Norrefalk 2007 ^194^ | treatment | treatment as usual | FALSE | FALSE | prospective
Norrefalk 2008 ^195^ | treatment, cost effectiveness | treatment as usual | FALSE | matched controls | prospective
Olason 2004 ^196^ | treatment | N/A | N/A | FALSE | prospective
Patrick 2004 ^197^ | treatment | non-MPP | FALSE | FALSE | Prospective
Perry 2010 ^77^ | treatment | usual care | FALSE | FALSE | prospective
Pfingsten 1997 ^74^ | treatment | N/A | N/A | FALSE | prospective
Polatin 1989 ^198^ | patient characteristics: predictive | No treatment and non-completers | FALSE | matched controls | Data collected prospectively
Polatin 1997 ^199^ | predictors | N/A | N/A | behavioral (Waddell signs) | Prospective
Proctor 2004 ^200^ | patient characteristics: predictive | N/A | N/A | FALSE | prospective
Proctor 2005 ^201^ | patient characteristics: predictive | N/A | N/A | non-completers | Prospective
Protas 2004 ^202^ | measurement validity | N/A | N/A | FALSE | prospective
Rainville 1992 ^203^ | patient characteristics | No treatment and non-completers | FALSE | FALSE | prospective
Rainville 1993 ^204^ | intervention mechanisms (cognitive) | No treatment and non-completers | FALSE | FALSE | prospective
Robbins 2003 ^38^ | treatment | Non-MPP (pts may not have actually received PT elsewhere) | FALSE | FALSE | Prospective
Rome 2004 ^205^ | patient characteristics: predictive | N/A | N/A | opioid use pre-treatment | retrospective
Sanders 1993 ^26^ | patient characteristics: predictive | N/A | N/A | FALSE | prospective
Scerri 2006 ^206^ | instrument utility, patient characteristics | N/A | N/A | cognitive/psychological, behavioral, radiographic abnormalities | Data collected prospectively
Scharff 1994 ^25^ | treatment | No treatment | FALSE | FALSE | prospective
Skinner 1990 ^207^ | treatment | N/A | N/A | FALSE | prospective
Skouen 2002 ^208^ | treatment, treatment component | non-MPP and no treatment | TRUE | FALSE | prospective
Skouen 2006 ^29^ | treatment, treatment component, patient characteristics (predictive) | non-MPP and no treatment | TRUE | FALSE | prospective
Snow 1988 ^209^ | treatment | N/A | N/A | FALSE | prospective
Snow 1990 ^210^ | treatment | N/A | N/A | FALSE | N/A
Spinhoven 2004 ^211^ | intervention mechanisms (cognitive) | MPP, waiting list | TRUE | FALSE | prospective
Stans 1989 ^212^ | treatment | N/A | N/A | FALSE | prospective
Sterner 2001 ^213^ | treatment | N/A | N/A | FALSE | prospective
Storro 2004 ^214^ | treatment | usual care | FALSE | diagnosis/pain location | prospective
Suman 2009 ^20^ | treatment | N/A | N/A | FALSE | prospective
Suoyrjo 2008 ^215^ | treatment | No treatment | FALSE | non-rehab, diagnosis/pain location | prospective
Tollison 1985 ^216^ | treatment | N/A | N/A | FALSE | prospective
Tollison 1989 ^217^ | treatment | N/A | N/A | acute vs. chronic pain | prospective
Tollison 1990 ^218^ | patient characteristics: predictive | N/A | N/A | compensated vs. noncompensated | prospective
Trief 1995 ^219^ | patient characteristics: predictive | N/A | N/A | FALSE | prospective
Turk 1998 ^12^ | treatment | N/A | N/A | FALSE | prospective
Turner-Stokes 2003 ^76^ | treatment | Non-MPP | TRUE | FALSE | prospective
van Wilgen 2009 ^220^ | treatment | waiting list period | FALSE | FALSE | prospective
Vendrig 1999 ^221^ | patient characteristics: predictive | N/A | N/A | FALSE | prospective
Vendrig 2000 ^222^ | patient characteristics: predictive | N/A | N/A | FALSE | prospective
Vendrig 2000 ^223^ | treatment | N/A | N/A | FALSE | prospective
Verra 2009 ^22^ | patient characteristics: predictive | N/A | N/A | FALSE | prospective
Vines 1996 ^224^ | treatment | N/A | N/A | FALSE | prospective
Vines 2000 ^225^ | treatment | N/A | N/A | FALSE | prospective
Vollenbroek-Hutten 2004 ^226^ | instrument utility, patient characteristics | usual care | 0 | cognitive/psychological | prospective
Vowles 2004 ^227^ | patient characteristics: predictive | N/A | N/A | FALSE | prospective
Vowles 2007 ^228^ | intervention mechanisms (cognitive) | N/A | N/A | FALSE | prospective
Vowles 2008 ^229^ | intervention mechanisms (cognitive) | N/A | N/A | FALSE | prospective
Vowles 2010 ^230^ | intervention mechanisms (cognitive) | N/A | N/A | FALSE | prospective
Walsh 2002 ^231^ | patient characteristics: predictive | N/A | N/A | FALSE | prospective
Walsh 2004 ^232^ | measurement validity | N/A | N/A | FALSE | prospective
Wang 2008 ^47^ | patient characteristics: predictive | N/A | N/A | healthy controls, TNF-alpha levels | prospective
Wasan 2004 ^233^ | treatment (ECT) | MPP | FALSE | matched controls (non-ECT) | retrospective
Williams 1993 ^234^ | treatment | N/A | N/A | FALSE | prospective
Williams 1999 ^49^ | study design validation | MPP, waiting list | Partially | randomized vs. did not consent to randomization | retrospective?
Wong 2009 ^235^ | treatment | N/A | N/A | FALSE | prospective
Wormgoor 2008 ^236^ | patient characteristics: predictive | N/A | N/A | diagnosis/pain location | prospective
Wright 1999 ^237^ | patient characteristics: predictive | N/A | N/A | diagnosis/pain location | Prospective
Zunin 2009 ^238^ | treatment | N/A | N/A | FALSE | prospective