# Search Strategy

## Concept Analysis

Three concepts relate to all key questions addressed in this Technical Brief. The concepts are (1) pain, (2) chronic, and (3) multidisciplinary treatment. Appendix Table C-1 explains the concept analysis and terminology that was used in searching Ovid MEDLINE^®^. MeSH terms (or other terms relevant to the specific bibliographic database as determined by database thesaurus) and text words (with truncation used as necessary) relating to each concept were aggregated. Concepts were combined together to compile a set of literature inclusive of all three concepts for screening. Limitations imposed on the Ovid MEDLINE^®^ search included human studies published in English. The search process was an iterative process with updates to restrict or expand the search as new terms are identified and the search process and resulting sets of literature are analyzed. The search below is the final search used.

Appendix Table C-1 Identification of search terms for relevant concepts

| | | Concepts
| | Pain | Chronic | Multidisciplinary Treatment
Search terms: (MeSH) and text words | Set A | Pain (MeSH) pain.mp neuralgia.mp | chronic.mp sustain*.mp intractable.mp. refractory.mp. persistent.mp. | Patient Care Team (MeSH) multidisciplinar$.tw interdisciplinar$.tw multiprofessional$.tw multimod$.tw (comprehensive adj2 program$).mp. (functional adj restor$).mp. (functional adj rehab$).mp.
Search terms: (MeSH) and text words | Set B | Pain clinics (MeSH)
MPP Literature Set = A + B

### Ovid MEDLINE(R) Search Strategy

Database: Ovid MEDLINE(R) <1950 to May Week 4 2010>

Search Strategy:

------------------------------------------------------------------------------------------

1. exp *Pain/
2. pain$.mp.
3. neuralg$.mp.
4. 1 or 2 or 3
5. chronic.tw.
6. sustain$.mp.
7. intractable.mp.
8. refractory.mp.
9. persistent.mp.
10. 5 or 6 or 7 or 8 or 9
11. exp *Pain Clinics/
12. (4 and 10) or 11
13. *Patient Care Team/
14. multidisciplinar$.mp.
15. interdisciplinar$.mp.
16. multiprofessional$.mp.
17. multimod$.mp.
18. (comprehensive adj2 program$).mp.
19. (functional adj restor$).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier]
20. (functional adj rehab$).mp.
21. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20
22. 12 and 21
23. exp Neoplasms/
24. cancer.mp.
25. exp Pain, Postoperative/
26. (post and (operative or surgical)).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier]
27. (“chest pain” or angina).mp.
28. pediatric.mp. or exp Pediatrics/
29. 23 or 24 or 25 or 26 or 27 or 28
30. 22 not 29
31. limit 30 to (english language and humans)
32. limit 31 to “all child (0 to 18 years)”
33. limit 32 to “all adult (19 plus years)”
34. 31 not 32
35. 34 or 33
36. limit 35 to yr=“1985-Current”
37. limit 36 to (addresses or bibliography or biography or dictionary or directory or in vitro or interactive tutorial or lectures or legal cases or legislation or letter or news or newspaper article or patient education handout or portraits)
38. 36 not 37
39. limit 38 to validation studies
40. 38 not 39

## Criteria for Inclusion/Exclusion of Studies in the Review

The two primary criteria that were used for inclusion/exclusion of studies pertain to population (i.e., adults with chronic noncancer pain) and treatment (multidisciplinary pain program defined as including at least four components – medical, behavioral, physical reconditioning, and educational). We included studies of any sample size, any design (RCT, controlled clinical trial, uncontrolled observational trial, and case reports/series) and studies that report any clinical outcome (e.g., quality of life, functioning, disability, and pain).

Studies were excluded based on the following exclusion criteria:

- Patients with cancer
- Patients with acute pain (e.g. pain less than 3 months and post-surgical pain)
- Patients who are ages 18 years or younger
- MPP studied does not include all four components: medical, behavioral, physical reconditioning, and educational.