# Key Informants and Potential Questions

## Key Informants

Name | Affiliation | Recommendation and Topic Area
Miles Belgrade, M.D. | Fairview Pain & Palliative Care Center | Recommended by EPC team Pain Program Medical Director Local content expert
Penney Cowan | American Chronic Pain Association (ACPA) | Recommended by SRC Consumer advocate, Executive Director of ACPA Patient with chronic pain who has experience with MPP
Debra Drew, M.S., R.N. | University of Minnesota Medical Center, Fairview | Clinical Nurse Specialist for Pain Management Local content expert
Alex Malter, M.D., M.P.H. | Medicaid Medical Director Alaska | Recommended by SRC Public payer perspective
Nina McIlree, M.D. | Zurich Services Corporation, Medical Director and Vice President of Medical Management Services | Recommended by Dr. Stanos Former attending physician at Rehabilitation Institute of Chicago; currently medical director for Work Comp
John Mullen, Ph.D., L.P. | Fairview Pain Management Center | Pain Program Psychologist Local content expert
Steven Stanos, D.O. | Rehabilitation Institute of Chicago Center for Pain Management | Recommended by local content experts Pain Program Medical Director National content expert, researcher American Pain Society leader
Dennis Turk, Ph.D. | University of Washington | Recommended by local content experts National content expert, researcher American Pain Society leader
Consumer 1 | | Patient with chronic pain who has experience with MPP
Consumer 2 | | Patient with chronic pain who has experience with MPP

## Guiding Questions for Key Informant Interviews

Third Party Payer Perspective: | 1. How do you define MPP (Multidisciplinary Pain Programs) eligibility for reimbursement as such?; 2. What do payers view as the advantages/disadvantages of MPPs?; 3. How do coverage policies impact the therapy components of MPPs?; 4. How does coverage impact patient access to MPPs?; 5. Are certain therapies for chronic pain more likely to be reimbursed by payers than others? If so, which therapies?; a. We have heard that some payers may be less likely to reimburse “mental health” services, but are willing to pay for “behavioral therapy” services. Have you found this to be true? What is the reasoning behind this difference?; 6. Is the managed care practice of separating out certain components of an MPP – i.e., “carve outs” - (e.g., PT or psychological services) increasing? If so, why?; 7. Is third party reimbursement for MPP becoming more or less restrictive?; 8. What information about MPPs is most needed by payers in making coverage decisions?; 9. What research questions (related to MPPs) would be most useful to payers? In studies evaluating the effectiveness of MPPs, what patient outcomes would be most useful or helpful to payer decisionmaking?
Consumer Perspective | 1. What has been your experience with Multidisciplinary Pain Programs (MPPs)?; a. What approaches had you tried before going to a MPP?; b. How did you hear about it?; 2. What did your MPP consist of? Which components were included: Physical therapy? Medical? Behavioral/psychological? Educational? (See Table on next page for examples of pain therapies). How long did you use the MPP?; 3. In what way(s), if any, did the MPP improve your ability to function?; 4. What were your expectations or goals for yourself in seeking care at the MPP? What were you hoping to achieve? Were your expectations/goals met? Why or why not?; 5. What would you consider “success” for a patient in a MPP?; 6. What do you view as the advantages/disadvantages of MPP?; 7. What component, if any, of the MPP did you find most helpful to you? And what component, if any, was least helpful?; Information needs for patients; 8 What information about MPPs would help you or other patients make a decision about seeking care at an MPP?; Insurance coverage; 9 Did you have any problems with reimbursement or coverage from your insurance company?
Expert Perspective (Researchers and Clinicians) | Patient access and referrals; 1. How available are Multidisciplinary Pain Programs (MPPs) to patients trying to access them? What are the barriers?; 2. What is your sense about MPPs increasing or decreasing in number? (based on what?); 3. Are community physicians generally aware of MPPs?; 4. What criteria are used to decide to refer patients to MPPs?; 5. In what ways could the referral process to MPP be improved?; Reimbursement issues; 6 How do payment rules or payer policies affect the therapy components of MPPs? (Table below); 7 Regarding the managed care practice of separating out certain components of an MPP – “carve outs” (e.g., PT or psychological services):; – What is the impact of this practice on patients? What is the impact on MPPs?; – Is this practice increasing? If so, why?; Administration and design of MPPs; 8 What type of staffing is desirable for an MPP?; 9 What type of staff training is desirable for an MPP?; 10 What role, if any, do accreditation programs have with MPPs? (e.g. AAPM); Patient experiences; 11 What is the main MPP “critique” received from patients, especially those who “drop out”?; Research; 12 What research on MPP is needed most? What would be a reasonable comparison group?; What outcomes are most important and when should they be measured (length of follow-up)?; 13 Should “interdisciplinary” be part of the standard definition of MPP for research (versus multi)?; Feedback on protocol; 14 How has the content of MPPs changed/evolved since their proliferation in the 1980's?; 15 Please review/comment on indicators/examples of each of four MPP components (see below).; a. Are the examples assigned to the correct component?; b. Are there any examples we should delete? Any examples we should add?; 16 Grey literature search: which professional organizations are important to consult regarding:; a. Consensus statements regarding multidisciplinary pain programs; b. Abstracts and/or preliminary study findings

Components of MPP | Examples and Indicators of Each Component
Medical | - Responsible for patient's physical well-being; - Manage medications; - Educational component may be included with medical (but research study must explicitly state this) e.g., neurophysiology education
Behavioral | - Responsible for psychosocial aspects of patients' care; - Cognitive Behavioral Therapy (CBT); - Operant Behavioral Therapy (OBT); - Stress management training; - Relaxation, progressive muscle relaxation; - Applied relaxation; - Biofeedback; - Behavioral therapy; - Comorbidity diagnosis and treatment; - Help patient unlearn maladaptive responses to pain; - Problem solving; - Individual or group psychotherapy; - Educational component is often included with behavioral (but research study must explicitly state this)
Physical Reconditioning | - Physical Therapy (PT) or Occupational Therapy (OT); - Upper extremity, ergonomic assessment and problem solving, work activities, leisure activities, ADLs.; - Graduated activity exposure (pacing) enabling patients to control exacerbations in pain by learning to regulate the activity and, once a regime of paced activity is established, to gradually increase their activity level; - Graded therapeutic exercises to safely increase functioning (e.g., flexibility, range of motion, posture, body mechanics, ambulation, gait training, core strength/stability, cardiovascular fitness, increasing upper and lower extremity strength and endurance; - Passive modes (e.g,. ultrasound, electrical stimulation, massage) are generally avoided in MPP and focus is teaching patients independent management of pain; - Stretching and strengthening emphasized; - Job analysis and reconditioning; - Aerobic exercises; - Exercise therapy; - Hydrotherapy, swimming; - Educational component is often included with Physical Reconditioning (but research study must explicitly state this), e.g., back education
Educational | - Improved self management is the focus; - Educational component is sometimes integrated with one or more other component - (e.g., by psychologist with behavioral component or by nurse with medical component or by PT with physical reconditioning component); - Back education; - Home exercise training; - Ergonomic training; - Neurophysiology education provided by a physician or nurse