# Terminology and Abbreviations

## Terminology

Multidisciplinary Pain Program: The multidisciplinary model of chronic pain treatment is based on the biopsychosocial model. This model emphasizes the complex and dynamic interaction between physiological, psychological, and social factors that serve to perpetuate and potentially worsen the pain experience. In contrast to the biomedical model, which emphasizes cure or at least elimination of a significant amount of pain, the goal of multidisciplinary pain programs is to restore physical and emotional functioning and improve overall quality of life (i.e., rehabilitation). An MPP includes the following four components: education, medical treatment, behavioral therapy, and physical reconditioning.
Partial Multidisciplinary Pain Program: A Partial MPP includes two or three, but not all four of the following components of an MPP: education, medical treatment, behavioral therapy, and physical reconditioning. In addition, the Partial MPP must be fundamentally rehabilitation in focus, i.e., the goal of the program is to restore physical and emotional functioning and improve overall quality of life.

## Abbreviations

CARF: Commission on Accreditation of Rehabilitation Facilities
CBT: Cognitive Behavioral Therapy
ICPM: Interdisciplinary Chronic Pain Management
IMMPACT: Initiative on Methods, Measurement, and Pain Assessment in Clinical Trials
IPRP: Interdisciplinary pain rehabilitation programs
MCO: Managed Care Organizations
MeSH: Medical Subject Headings
MPP: Multidisciplinary Pain Program
MPRP: Multidisciplinary Pain Rehabilitation Centers
OBT: Operant Behavioral Therapy
OT: Occupational Therapy/Therapist
PT: Physical Therapy/Therapist
VAS: Visual analog scale