# Summary and Implications

Musculoskeletal disorders, particularly those of the back and knee, are a significant and growing source of pain and disability. The limitations of standard closed-bore magnetic resonance imaging (MRI) have created interest in combining stress-loading approaches with MRI technology to generate more clinically useful images. The set of possible features of emerging MRI technologies for evaluating patients with musculoskeletal symptoms under loading stress includes: high image quality and speed, ability to image the joint under stress, ability to image joints in symptomatic positions, ability to obtain dynamic imaging, and patient comfort and safety. We compared these features between competing emerging technologies and summarized their theoretical advantages and disadvantages (Table 3).

Although the postulated advantages of stress-loading MRI seem promising, the diagnostic validity and clinical usefulness of stress-loading MRI in the management of musculoskeletal disorders is not clear. Clinician and insurance payer (both public and private) key informants (KIs)also expressed concerns regarding the clinical use of stress-loading MRI; current guidelines do not recommend the use of MRI under stress loading.112 To date, only a few published studies compare stress-loading MRI with contemporary imaging alternatives, or report outcomes beyond anatomical changes (see the Evidence Map subsection of the Findings section of this report). Moreover, specific indications and clinical settings where stress-loading MRI should be obtained have not been fully elucidated or evaluated, and most of the existing studies appear to have serious methodological limitations.109 A key issue was t he impact of low-field strength on the image quality of stress-loading MRI devices. This was compounded by the inadequate evidence basis supporting the superiority (or even equivalence) of stress-loading MRI to conventional imaging alternatives.

Our findings emphasize the existing clinical need for improving the diagnostic performance of MRI examinations but also highlight the risks of bringing to clinical use imaging modalities with uncertain clinical utility. A combined assessment of past trends in the growth of MRI imaging in the United States and the interest in the field expressed by clinicians, researchers, and device manufacturers suggests that further increases in the use of stress-loading MRI may be expected in the future. Increasing use of conventional MRI has been associated with increased utilization of orthopedic surgical procedures, with unclear effects on patient outcomes. The apparent limited impact of MRI on patient outcomes may be due to the limited ability of MRI to discriminate between patients who require intervention and those who do not, as indicated by the high frequency of positive MRI exams on clinically asymptomatic patients.13,17,18,110–113 Currently, the published evidence on stress-loading MRI is inadequate to determine whether use of these devices will improve patient outcomes compared to conventional imaging techniques.

The number of deployed stress-loading MRI scanners appears to be relatively low; the device types for which we were able to obtain specific estimates of the number of installed scanners appear to have an installed base of only a few hundred units in the United States. However, according to KI feedback, stress-loading MRIs are rapidly evolving imaging modalities, and, given the rapid patterns of growth evident worldwide for MRI availability and utilization, it is expected that their use will continue to grow. Manufacturers of these devices are actively marketing their devices for clinical use, and some radiology practices are directly marketing stress-loading MRI to consumers. The diversity of existing stress-loading applications and the emergence of new technologies are a cause of concern among health professionals and policy-makers, particularly regarding their imaging quality and cost effectiveness.

Although all commercially available stress-loading MRIs we reviewed are considered as “substantially equivalent” to conventional MRI by the FDA, given the potential implications of an incorrect diagnosis, we argue that further validation of the diagnostic accuracy and clinical utility of these devices is necessary. Both false positive and false negative results may have serious consequences, such as suggesting (when not necessary) or delaying (when needed) surgical or other treatments for musculoskeletal conditions. In addition, MRI may be used as part of the investigation of worker compensation claims or for evidentiary purposes and should therefore be thoroughly vetted as valid means of establishing injury.^c^

c For example, see http://www.fonar.com/news/072110.htm and http://www.dynawell.biz/spinalinfo_conditions.htm (section on sciatica), both accessed on October 11, 2010)

As shown in the Evidence Map subsection of the Findings section of this report, the published evidence on stress-loading MRI is of poor methodological quality and the majority of studies reviewed did not report clinical outcomes. As such, the clinical utility of these imaging devices is unclear. We identified no randomized or nonrandomized comparative studies of testing strategies for stress-loading MRI. Comparative studies of diagnostic tests applied to the same individuals were few, had small sample sizes, and reported on heterogeneous, typically surrogate outcomes. There was little or no evidence regarding the impact of these tests on physician’s diagnostic thinking or decision-making with regards to treatment. The relative costs and benefits of these technologies are unclear; no formal quantitative assessment was identified by our literature searches. Box 1 summarizes the key decisionmaking uncertainties we identified regarding weight-bearing and stress-loading MRI.

Box 1 Key decisionmaking uncertainties for weight-bearing and stress-loading MRI

- Do the new features of emerging MRI technologies (such as stress loading, open configuration, and positioning) translate into improved diagnostic accuracy?
  The diagnostic accuracy of the available weight-bearing and stress-loading MRI methods has not been investigated in large, well-designed studies for any of the stress-loading devices we considered. Consequently, the validity of claims concerning the diagnostic superiority of stress loading over conventional MRI has not been tested.
- How do these technologies affect physicians’ diagnostic thinking or decisionmaking with regard to treatment, or patient outcomes?
  There is very little available evidence on how stress-loading MRI influences diagnostic or treatment decisions.
- Are there subgroups of patients (either in terms of disease or at a specific stage in the diagnostic process) for whom MRI under loading stress would be indicated?
  It is currently unclear if these technologies have higher diagnostic accuracy or improve outcomes among specific subgroups of patients.
- What is the clinical setting where such imaging would be most beneficial?
  Based on studies conducted to date, the clinical setting where stress-loading MRI would have maximal utility remains undefined.
- What are the consequences of false positive or negative findings?
  Given the absence of well-designed studies linking diagnostic testing with patient outcomes, it is difficult to estimate potential harms from over-treatment or missed diagnoses.
- What is the cost-effectiveness of these methods?
  Although modeling of cost-effectiveness would be possible given the available data, it is likely that there would be considerable uncertainty regarding the optimal diagnostic strategy given the small sample sizes and methodological limitations of existing studies. Modeling may be more informative after additional data on diagnostic validity become available.