# References

1 Haralson RH III, Zuckerman JD. Prevalence, Health Care Expenditures, and Orthopedic Surgery Workforce for Musculoskeletal Conditions. JAMA: The Journal of the American Medical Association. 2009;302:1586-7.
2 Centers for Disease Control and Prevention. Prevalence of Disabilities and Associated Health Conditions Among Adults: United States, 1999. MMWR Morb Mortal Wkly Rep. 2001;50:120-5. [pmid: 11393491].
3 Freburger JK, Holmes GM, Agans RP, et al. The rising prevalence of chronic low back pain. Arch Intern Med. 2009;169:251-8. [pmid: 19204216].
4 Jarvik JG, Deyo RA. Diagnostic evaluation of low back pain with emphasis on imaging. Ann Intern Med. 2002;137:586-97. [pmid: 12353946].
5 Stewart WF, Ricci JA, Chee E, et al. Lost productive time and cost due to common pain conditions in the US workforce. JAMA. 2003;290:2443-54. [pmid: 14612481].
6 Stewart WF, Ricci JA, Chee E, et al. Lost productive work time costs from health conditions in the United States: results from the American Productivity Audit. J Occup Environ Med. 2003;45:1234-46. [pmid: 14665809].
7 Juniper M, Le TK, Mladsi D. The epidemiology, economic burden, and pharmacological treatment of chronic low back pain in France, Germany, Italy, Spain and the UK: a literature-based review. Expert Opin Pharmacother. 2009;10:2581-92. [pmid: 19874246].
8 Kasper DL, Braunwald E, Fauci AS, et al. Harrison’s principles of internal medicine. 17th ed. New York. McGraw-Hill Medical Publishing Division. 2008.
9 Novelline RA. Squire’s Fundamentals of Radiology. 6th ed. Cambridge, MA. Harvard University Press. 2004.
10 Sprawls P Jr. Physical Principles of Medical Imaging. 2nd ed. Gaithersburg, MD. Aspen Publishers. 1993.
11 Wolbarst AB. Physics of Radiology. Norwalk, CT. Appleton & Lange. 1993.
12 OECD Directorate for Employment, Labour and Social Affairs. Health Data 2010 - Frequently Requested Data. Directorate for Employment, Labour and Social Affairs. 2010. Available at: http://www.oecd.org/document/16/0,3343,en_2649_34631_2085200_1_1_1_1,00.html. Accessed October 11, 2010.
13 Roudsari B, Jarvik JG. Lumbar spine MRI for low back pain: indications and yield. AJR Am J Roentgenol. 2010;195:550-9. [pmid: 20729428].
14 Deyo RA, Mirza SK, Turner JA, et al. Over treating chronic back pain: time to back off?. J Am Board Fam Med. 2009;22:62-8. [pmid: 19124635].
15 Mitchell JM. Utilization trends for advanced imaging procedures: evidence from individuals with private insurance coverage in California. Med Care. 2008;46:460-6. [pmid: 18438193].
16 Weiner DK, Kim YS, Bonino P, et al. Low back pain in older adults: are we utilizing healthcare resources wisely?. Pain Med. 2006;7:143-50. [pmid: 16634727].
17 Deyo RA, Nachemson A, Mirza SK. Spinal-fusion surgery - the case for restraint. N Engl J Med. 2004;350:722-6. [pmid: 14960750].
18 Jarvik JJ, Hollingworth W, Heagerty P, et al. The Longitudinal Assessment of Imaging and Disability of the Back (LAIDBack) Study: baseline data. Spine (Phila Pa 1976 ). 2001;26:1158-66. [pmid: 11413431].
19 Jensen MC, Brant-Zawadzki MN, Obuchowski N, et al. Magnetic resonance imaging of the lumbar spine in people without back pain. N Engl J Med. 1994;331:69-73. [pmid: 8208267].
20 Stadnik TW, Lee RR, Coen HL, et al. Annular tears and disk herniation: prevalence and contrast enhancement on MR images in the absence of low back pain or sciatica. Radiology. 1998;206:49-55. [pmid: 9423651].
21 Takatalo J, Karppinen J, Niinimaki J, et al. Prevalence of degenerative imaging findings in lumbar magnetic resonance imaging among young adults. Spine (Phila Pa 1976 ). 2009;34:1716-21. [pmid: 19770614].
22 Capel A, Medina FS, Medina D, et al. Magnetic resonance study of lumbar disks in female dancers. Am J Sports Med. 2009;37:1208-13. [pmid: 19417120].
23 Melendez JC, McCrank E. Anxiety-related reactions associated with magnetic resonance imaging examinations. JAMA. 1993;270:745-7. [pmid: 8336378].
24 Skelly AC, Moore E, Dettori JR. Comprehensive Evidence-Based Health Technology Assessment: Effectiveness of Upright MRI for Evaluation of Patients With Suspected Spinal or Extra-Spinal Joint Dysfunction (Prepared by Spetrum Research, Inc.). Olympia, WA. Washington State Health Care Authority. 2007.
25 Ferreiro PA, Garcia IM, Ayerbe E, et al. Evaluation of intervertebral disc herniation and hypermobile intersegmental instability in symptomatic adult patients undergoing recumbent and upright MRI of the cervical or lumbosacral spines. European Journal of Radiology. 2007;62:444-8. [pmid: 17412542].
26 Madsen R, Jensen TS, Pope M, et al. The effect of body position and axial load on spinal canal morphology: an MRI study of central spinal stenosis. Spine. 2008;33:61-7. [pmid: 18165750].
27 Zou J, Yang H, Miyazaki M, et al. Missed lumbar disc herniations diagnosed with kinetic magnetic resonance imaging. Spine. 2008;33:E140-4. [pmid: 18317181].
28 Zou J, Yang H, Miyazaki M, et al. Dynamic bulging of intervertebral discs in the degenerative lumbar spine. Spine. 2009;34:2545-50. [pmid: 19841611].
29 Sistrom CL, McKay NL. Costs, charges, and revenues for hospital diagnostic imaging procedures: differences by modality and hospital characteristics. J Am Coll Radiol. 2005;2:511-19. [pmid: 17411868].
30 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. 1991;11:88-94. [pmid: 1907710].
31 Gurtcheff SE. Introduction to the MAUDE database. Clin Obstet Gynecol. 2008;51:120-3. [pmid: 18303506].
32 Hetrick SE, Parker AG, Callahan P, et al. Evidence mapping: illustrating an emerging methodology to improve evidence-based practice in youth mental health. J Eval Clin Pract. 2010.
33 Lauritsen JM, Bruus M. EpiData Entry (version 3.1). A comprehensive tool for validated entry and documentation of data. The EpiData Association. Odense Denmark. 2004. Version 3.1.
34 Altman DG, Bland JM. Presentation of numerical data. BMJ. 1996;312:572. [pmid: 8595293].
35 Chapman BLW. Gradients: The Heart of the MRI Machine. Current Medical Imaging Reviews. 2006;2:131-8.
36 Salustri C, Yang Y, Glover GH. Simple but reliable solutions for spiral MRI gradient design. J Magn Reson. 1999;140:347-50. [pmid: 10497042].
37 While PT, Forbes LK, Crozier S. 3-D gradient coil design--initial theoretical framework. IEEE Trans Biomed Eng. 2009;56:1169-83. [pmid: 19174330].
38 Premera Blue Cross. Positional MRI, Corporate Medical Policy. 2010. Available at: https://www.premera.com/stellent/groups/public/documents/medicalpolicy/cmi_039653.pdf. Accessed November 11, 2010.
39 Rutt BK, Lee DH. The impact of field strength on image quality in MRI. J Magn Reson Imaging. 1996;6:57-62. [pmid: 8851404].
40 Hidalgo-Tobon SS. Theory of gradient coil design methods for magnetic resonance imaging. Concepts Magn Reson. 2010;36A:223-42.
41 Kanal E, Borgstede JP, Barkovich AJ, et al. American College of Radiology White Paper on MR Safety. AJR Am J Roentgenol. 2002;178:1335-47. [pmid: 12034593].
42 U.S. Food and Drug Administration. MRI Safety. 2009. Available at: http://www.fda.gov/MedicalDevices/Safety/AlertsandNotices/ucm135362.htm. Accessed November 19, 2010.
43 ECRI. What’s new in MR safety: the latest on the safe use of equipment in the magnetic resonance environment. Health Devices. 2005;34:333-49. [pmid: 16355927].
44 U.S. Food and Drug Administration. MAUDE Adverse Event Report, July 21, 2006. Available at: http://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/PostmarketRequirements/ReportingAdverseEvents/ucm127891.htm. Accessed October 10, 2010.
45 U.S. Food and Drug Administration. MAUDE Adverse Event Report, May 15, 2009. Available at: http://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/PostmarketRequirements/ReportingAdverseEvents/ucm127891.htm. Accessed October 10, 2010.
46 U.S. Food and Drug Administration. MAUDE Adverse Event Report, October 26, 2007. Available at: http://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/PostmarketRequirements/ReportingAdverseEvents/ucm127891.htm. Accessed October 10, 2010.
47 DeLuca SA, Castronovo FP Jr. Hazards of magnetic resonance imaging. Am Fam Physician. 1990;41:145-46. [pmid: 2294670].
48 Murphy KJ, Brunberg JA. Adult claustrophobia, anxiety and sedation in MRI. Magn Reson Imaging. 1997;15:51-4. [pmid: 9084025].
49 Westra AE, Zegers MP, Sukhai RN, et al. Discomfort in children undergoing unsedated MRI. Eur J Pediatr. 2010.
50 Springer F, Machann J, Schwenzer NF, et al. Quantitative assessment of intrahepatic lipids using fat-selective imaging with spectral-spatial excitation and in-/opposed-phase gradient echo imaging techniques within a study population of extremely obese patients: feasibility on a short, wide-bore MR scanner. Invest Radiol. 2010;45:484-90. [pmid: 20479651].
51 Kuhn JP, Langner S, Hegenscheid K, et al. Magnetic resonance-guided upper abdominal biopsies in a high-field wide-bore 3-T MRI system: feasibility, handling, and needle artefacts. Eur Radiol. 2010;20:2414-21. [pmid: 20503050].
52 Boss A, Rempp H, Martirosian P, et al. Wide-bore 1.5 Tesla MR imagers for guidance and monitoring of radiofrequency ablation of renal cell carcinoma: initial experience on feasibility. Eur Radiol. 2008;18:1449-55. [pmid: 18351355].
53 Aetna, Inc. Clinical Policy Bulletin: Open Air, Low Field Strength, and Positional MRI Units. Number 0093. Updated March 19, 2010. Aetna. Available at: http://www.aetna.com/cpb/medical/data/1_99/0093.html. Accessed October 7, 2010.
54 FONAR Corporation. FONAR Announces Financial Results for First Quarter of Fiscal 2010. FONAR Corporation. 11. 23. 2009. Available at: http://www.fonar.com/news/112309.htm. Accessed October 10, 2010.
55 DynaWell Diagnostics. DynaWell L-spine compression device. 2010. Available at: http://www.dynawelldiagnostics.com/. Accessed October 10, 2010.
56 Draper CE, Besier TF, Santos JM, et al. Using real-time MRI to quantify altered joint kinematics in subjects with patellofemoral pain and to evaluate the effects of a patellar brace or sleeve on joint motion. Journal of Orthopaedic Research. 2009;27:571-7. [pmid: 18985690].
57 Beastall J, Karadimas E, Siddiqui M, et al. The Dynesys lumbar spinal stabilization system: a preliminary report on positional magnetic resonance imaging findings. Spine. 2007;32:685-90. [pmid: 17413475].
58 Boxheimer L, Lutz AM, Zanetti M, et al. Characteristics of displaceable and nondisplaceable meniscal tears at kinematic MR imaging of the knee. Radiology. 2006;238:221-31. [pmid: 16373770].
59 Daffner SD, Xin J, Taghavi CE, et al. Cervical segmental motion at levels adjacent to disc herniation as determined with kinetic magnetic resonance imaging. Spine. 2009;34:2389-94. [pmid: 19829252].
60 Hebert LJ, Moffet H, Dufour M, et al. Acromiohumeral distance in a seated position in persons with impingement syndrome. J Magn Reson Imaging. 2003;18:72-9. [pmid: 12815642].
61 Kulig K, Powers CM, Landel RF, et al. Segmental lumbar mobility in individuals with low back pain: in vivo assessment during manual and self-imposed motion using dynamic MRI. BMC Musculoskeletal Disorders. 2007;8:8. [pmid: 17261197].
62 Logan M, Dunstan E, Robinson J, et al. Tibiofemoral kinematics of the anterior cruciate ligament (ACL)-deficient weightbearing, living knee employing vertical access open “interventional” multiple resonance imaging. American Journal of Sports Medicine. 2004;32:720-6. [pmid: 15090390].
63 Logan MC, Williams A, Lavelle J, et al. Tibiofemoral kinematics following successful anterior cruciate ligament reconstruction using dynamic multiple resonance imaging. American Journal of Sports Medicine. 2004;32:984-92. [pmid: 15150047].
64 Morishita Y, Naito M, Hymanson H, et al. The relationship between the cervical spinal canal diameter and the pathological changes in the cervical spine. European Spine Journal. 2009;18:877-83. [pmid: 19357877].
65 Nath RK, Paizi M, Melcher SE, et al. Upright MRI of glenohumeral dysplasia following obstetric brachial plexus injury. Magnetic Resonance Imaging. 2007;25:1277-82. [pmid: 17448618].
66 Siddiqui M, Karadimas E, Nicol M, et al. Influence of X Stop on neural foramina and spinal canal area in spinal stenosis. Spine. 2006;31:2958-62. [pmid: 17139227].
67 Siddiqui M, Nicol M, Karadimas E, et al. The positional magnetic resonance imaging changes in the lumbar spine following insertion of a novel interspinous process distraction device. Spine. 2005;30:2677-82. [pmid: 16319754].
68 Steiner ME, Koskinen SK, Winalski CS, et al. Dynamic lateral patellar tilt in the anterior cruciate ligament-deficient knee. A magnetic resonance imaging analysis. American Journal of Sports Medicine. 2001;29:593-9. [pmid: 11573918].
69 Vitaz TW, Shields CB, Raque GH, et al. Dynamic weight-bearing cervical magnetic resonance imaging: technical review and preliminary results. Southern Medical Journal. 2004;97:456-61. [pmid: 15180020].
70 Weishaupt D, Schmid MR, Zanetti M, et al. Positional MR imaging of the lumbar spine: does it demonstrate nerve root compromise not visible at conventional MR imaging?. Radiology. 2000;215:247-53. [pmid: 10751495].
71 Weishaupt D, Treiber K, Kundert HP, et al. Morton neuroma: MR imaging in prone, supine, and upright weight-bearing body positions. Radiology. 2003;226:849-56. [pmid: 12601213].
72 Powers CM, Beneck GJ, Kulig K. Effects of a single session of posterior-to-anterior spinal mobilization and press-up exercise on pain response and lumbar spine extension in people with nonspecific low back pain. Physical Therapy. 2008:485-93. [pmid: 18258767].
73 Sutera R, Iovane A, Sorrentino F, et al. Plantar fascia evaluation with a dedicated magnetic resonance scanner in weight-bearing position: our experience in patients with plantar fasciitis and in healthy volunteers. Radiologia Medica. 2010;115:246-60. [pmid: 20177977].
74 Karadimas EJ, Siddiqui M, Smith FW, et al. Positional MRI changes in supine versus sitting postures in patients with degenerative lumbar spine. Journal of Spinal Disorders & Techniques. 2006;19:495-500. [pmid: 17021413].
75 Morishita Y, Hymanson H, Miyazaki M, et al. Kinematic evaluation of the spine: a kinetic magnetic resonance imaging study. Journal of Orthopaedic Surgery. 2008;16:348-50. [pmid: 19126904].
76 Logan MC, Williams A, Lavelle J, et al. What really happens during the Lachman test? A dynamic MRI analysis of tibiofemoral motion. [Erratum appears in Am J Sports Med. 2004 Apr-May;32(3):824]. American Journal of Sports Medicine. 2004;32:369-75. [pmid: 14977660].
77 McGregor A, Anderton L, Gedroyc W. The assessment of intersegmental motion and pelvic tilt in elite oarsmen. Medicine & Science in Sports & Exercise. 2002;34:1143-9. [pmid: 12131255].
78 McGregor AH, Anderton L, Gedroyc WM. The trunk muscles of elite oarsmen. British Journal of Sports Medicine. 2002;36:214-17. [pmid: 12055118].
79 McGregor AH, Anderton L, Gedroyc WM, et al. The use of interventional open MRI to assess the kinematics of the lumbar spine in patients with spondylolisthesis. Spine. 2002;27:1582-6. [pmid: 12131722].
80 Zamani AA, Moriarty T, Hsu L, et al. Functional MRI of the lumbar spine in erect position in a superconducting open-configuration MR system: preliminary results. J Magn Reson Imaging. 1998;8:1329-33. [pmid: 9848747].
81 Siddiqui M, Karadimas E, Nicol M, et al. Effects of X-STOP device on sagittal lumbar spine kinematics in spinal stenosis. Journal of Spinal Disorders & Techniques. 2006;19:328-33. [pmid: 16826003].
82 Wildermuth S, Zanetti M, Duewell S, et al. Lumbar spine: quantitative and qualitative assessment of positional (upright flexion and extension) MR imaging and myelography. [Erratum appears in Radiology 1998 Sep;208(3):834]. Radiology. 1998;207:391-8. [pmid: 9577486].
83 Lee SU, Lee JI, Butts K, et al. Changes in posterior lumbar disk contour abnormality with flexion-extension movement in subjects with low back pain and degenerative disk disease. Pm & R. 2009;1:541-6. [pmid: 19627944].
84 Vitzthum HE, Konig A, Seifert V. Dynamic examination of the lumbar spine by using vertical, open magnetic resonance imaging. Journal of Neurosurgery. 2000;93:Suppl–64.
85 Manenti G, Liccardo G, Sergiacomi G, et al. Axial loading MRI of the lumbar spine. In Vivo. 2003;17:413-20. [pmid: 14598603].
86 Shellock FG, Mink JH, Deutsch AL, et al. Patellofemoral joint: identification of abnormalities with active-movement, “unloaded” versus “loaded” kinematic MR imaging techniques. Radiology. 1993;188:575-8. [pmid: 8327718].
87 Danielson BI, Willen J, Gaulitz A, et al. Axial loading of the spine during CT and MR in patients with suspected lumbar spinal stenosis. Acta Radiologica. 1998;39:604-11. [pmid: 9817029].
88 Hansson T, Suzuki N, Hebelka H, et al. The narrowing of the lumbar spinal canal during loaded MRI: the effects of the disc and ligamentum flavum. European Spine Journal. 2009;18:679-86. [pmid: 19277726].
89 Huang KY, Lin RM, Lee YL, et al. Factors affecting disability and physical function in degenerative lumbar spondylolisthesis of L4–5: evaluation with axially loaded MRI. European Spine Journal. 2009;18:1851-7. [pmid: 19526378].
90 Adam C, Izatt M, Askin G. Design and evaluation of an MRI compatible axial compression device for 3D assessment of spinal deformity and flexibility in AIS. Studies in Health Technology & Informatics. 2010;158:38-43. [pmid: 20543397].
91 Ward SR, Terk MR, Powers CM. Influence of patella alta on knee extensor mechanics. Journal of Biomechanics. 2005;38:2415-22. [pmid: 16214489].
92 Ahn TJ, Lee SH, Choi G, et al. Effect of intervertebral disk degeneration on spinal stenosis during magnetic resonance imaging with axial loading. Neurologia Medico-Chirurgica. 247;49:242-7.
93 Patel VV, Hall K, Ries M, et al. A three-dimensional MRI analysis of knee kinematics. Journal of Orthopaedic Research. 2004;22:283-92. [pmid: 15013086].
94 Wang YC, Jeng CM, Wu CY, et al. Dynamic effects of axial loading on the lumbar spine during magnetic resonance imaging in patients with suspected spinal stenosis. Journal of the Formosan Medical Association. 2008;107:334-9. [pmid: 18445548].
95 McWalter EJ, Cibere J, MacIntyre NJ, et al. Relationship between varus-valgus alignment and patellar kinematics in individuals with knee osteoarthritis. Journal of Bone & Joint Surgery - American Volume. 2007;89:2723-31.
96 Willen J, Danielson B. The diagnostic effect from axial loading of the lumbar spine during computed tomography and magnetic resonance imaging in patients with degenerative disorders. Spine. 2001;26:2607-14. [pmid: 11725243].
97 Shefelbine SJ, Ma CB, Lee KY, et al. MRI analysis of in vivo meniscal and tibiofemoral kinematics in ACL-deficient and normal knees. Journal of Orthopaedic Research. 2006;24:1208-17. [pmid: 16652339].
98 Willen J, Wessberg PJ, Danielsson B. Surgical results in hidden lumbar spinal stenosis detected by axial loaded computed tomography and magnetic resonance imaging: an outcome study. Spine. 2008;33:E109-15. [pmid: 18277859].
99 Ward SR, Terk MR, Powers CM. Patella alta: association with patellofemoral alignment and changes in contact area during weight-bearing. Journal of Bone & Joint Surgery - American Volume. 2007;89:1749-55.
100 Wessberg P, Danielson BI, Willen J. Comparison of Cobb angles in idiopathic scoliosis on standing radiographs and supine axially loaded MRI. Spine. 2006;31:3039-44. [pmid: 17173001].
101 Miyazaki M, Morishita Y, Takita C, et al. Analysis of the relationship between facet joint angle orientation and lumbar spine canal diameter with respect to the kinematics of the lumbar spinal unit. Journal of Spinal Disorders & Techniques. 2010;23:242-8. [pmid: 20068469].
102 Kimura S, Hesselink JR, Garfin SR, et al. Axial load-dependent cervical spinal alterations during simulated upright posture: a comparison of healthy controls and patients with cervical degenerative disease. Journal of Neurosurgery Spine. 2005;2:137-44. [pmid: 15739524].
103 Shellock FG. Effect of a patella-stabilizing brace on lateral subluxation of the patella: assessment using kinematic MRI. American Journal of Knee Surgery. 2000;13:137-42. [pmid: 11277241].
104 Hiwatashi A, Danielson B, Moritani T, et al. Axial loading during MR imaging can influence treatment decision for symptomatic spinal stenosis. AJNR Am J Neuroradiol. 2004;25:170-4. [pmid: 14970014].
105 Willen J, Danielson B, Gaulitz A, Niklason T, et al. Dynamic effects on the lumbar spinal canal: axially loaded CT-myelography and MRI in patients with sciatica and/or neurogenic claudication. Spine (Phila Pa 1976 ). 1997;22:2968-76. [pmid: 9431634].
106 Kong MH, Hymanson HJ, Song KY, et al. Kinetic magnetic resonance imaging analysis of abnormal segmental motion of the functional spine unit. J Neurosurg Spine. 2009;10:357-65. [pmid: 19441995].
107 Kong MH, Morishita Y, He W, et al. Lumbar segmental mobility according to the grade of the disc, the facet joint, the muscle, and the ligament pathology by using kinetic magnetic resonance imaging. Spine (Phila Pa 1976 ). 2009;34:2537-44. [pmid: 19841613].
108 FONAR Corporation. The Multi-Positional Extremity MRI. FONAR Corporation. 2003. Available at: http://www.fonar.com/mpextremity.htm. Accessed October 11, 2010.
109 Low back disorders, Occupational medicine practice guidelines: evaluation and management of common health problems and functional recovery in workers. American College of Occupational and Environmental Medicine. 2nd ed. Elk Grove Village, IL. 2007.
110 Jensen MC, Brant-Zawadzki MN, Obuchowski N, et al. Magnetic resonance imaging of the lumbar spine in people without back pain. N Engl J Med. 1994;331:69-73. [pmid: 8208267].
111 Stadnik TW, Lee RR, Coen HL, et al. Annular tears and disk herniation: prevalence and contrast enhancement on MR images in the absence of low back pain or sciatica. Radiology. 1998;206:49-55. [pmid: 9423651].
112 Takatalo J, Karppinen J, Niinimaki J, et al. Prevalence of degenerative imaging findings in lumbar magnetic resonance imaging among young adults. Spine (Phila Pa 1976 ). 2009;34:1716-21. [pmid: 19770614].
113 Capel A, Medina FS, Medina D, et al. Magnetic resonance study of lumbar disks in female dancers. Am J Sports Med. 2009;37:1208-13. [pmid: 19417120].
114 Lijmer JG, Leeflang M, Bossuyt PM. Proposals for a phased evaluation of medical tests. Med Decis Making. 2009;29:E13-21. [pmid: 19605881].
115 Lijmer JG, Mol BW, Heisterkamp S, et al. Empirical evidence of design-related bias in studies of diagnostic tests. JAMA. 1999;282:1061-6. [pmid: 10493205].
116 Rothman K, Greenland S. Modern Epidemiology. 2nd ed. Lippincott Williams and Wilkins. 1998.
117 Bossuyt PM, Reitsma JB, Bruns DE, et al. The STARD Statement for Reporting Studies of Diagnostic Accuracy: Explanation and Elaboration. Clin Chem. 2003;49:7-18. [pmid: 12507954].
118 Bossuyt PM, Reitsma JB, Bruns DE, et al. Towards complete and accurate reporting of studies of diagnostic accuracy: The STARD Initiative. Ann Intern Med. 2003;138:40-4. [pmid: 12513043].
119 Whiting P, Rutjes A, Reitsma J, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Medical Research Methodology. 2003;3:25. [pmid: 14606960].
120 Gart JJ, Buck AA. Comparison of a screening test and a reference test in epidemiologic studies. II. A probabilistic model for the comparison of diagnostic tests. Am J Epidemiol. 1966;83:593-602. [pmid: 5932703].
121 Hui SL, Walter SD. Estimating the error rates of diagnostic tests. Biometrics. 1980;36:167-71. [pmid: 7370371].
122 Johnson WO, Gastwirth JL, Pearson LM. Screening without a “gold standard”: the Hui-Walter paradigm revisited. Am J Epidemiol. 2001;153:921-4. [pmid: 11323324].
123 Reitsma JB, Rutjes AW, Khan KS, et al. A review of solutions for diagnostic accuracy studies with an imperfect or missing reference standard. J Clin Epidemiol. 2009;62:797-806. [pmid: 19447581].
124 Bland JM, Altman DG. Statistical methods for assessing agreement between two methods of clinical measurement. Lancet. 1986;1:307-10. [pmid: 2868172].
125 Lin LI. A concordance correlation coefficient to evaluate reproducibility. Biometrics. 1989;45:255-68. [pmid: 2720055].
126 Cohen J. Weighted kappa: nominal scale agreement with provision for scaled disagreement or partial credit. Psychol Bull. 1968;70:213-20. [pmid: 19673146].
127 Joseph L, Gyorkos TW, Coupal L. Bayesian estimation of disease prevalence and the parameters of diagnostic tests in the absence of a gold standard. Am J Epidemiol. 1995;141:263-72. [pmid: 7840100].
128 Walter SD, Irwig LM. Estimation of test error rates, disease prevalence and relative risk from misclassified data: a review. J Clin Epidemiol. 1988;41:923-37. [pmid: 3054000].
129 Dixon AK. The impact of medical imaging on the physician’s diagnostic and therapeutic thinking. Eur Radiol. 1998;8:488-90. [pmid: 9510594].
130 Ng CS, Palmer CR. Assessing diagnostic confidence: a comparative review of analytical methods. Acad Radiol. 2008;15:584-92. [pmid: 18423315].
131 Bossuyt PM, Lijmer JG, Mol BW. Randomised comparisons of medical tests: sometimes invalid, not always efficient. Lancet. 2000;356:1844-7. [pmid: 11117930].
132 Lord SJ, Irwig L, Bossuyt PM. Using the principles of randomized controlled trial design to guide test evaluation. Med Decis Making. 2009;29:E1-12. [pmid: 19773580].
133 Lord SJ, Irwig L, Simes RJ. When is measuring sensitivity and specificity sufficient to evaluate a diagnostic test, and when do we need randomized trials?. Ann Intern Med. 2006;144:850-5. [pmid: 16754927].
134 Trikalinos TA, Siebert U, Lau J. Decision-analytic modeling to evaluate benefits and harms of medical tests: uses and limitations. Med Decis Making. 2009;29:E22-9. [pmid: 19734441].
135 Schaafsma JD, van der GY, Rinkel GJ, et al. Decision analysis to complete diagnostic research by closing the gap between test characteristics and cost-effectiveness. J Clin Epidemiol. 2009;62:1248-52. [pmid: 19364636].
136 Lijmer JG, Bossuyt PM. Various randomized designs can be used to evaluate medical tests. J Clin Epidemiol. 2009;62:364-73. [pmid: 18945590].
137 Rutjes AW, Reitsma JB, Di NM, et al. Evidence of bias and variation in diagnostic accuracy studies. CMAJ. 2006;174:469-76. [pmid: 16477057].