# Next Steps

## Conceptual Framework for Future Research and Policy

In this Technical Brief, we have organized emerging magnetic resonance imaging (MRI) devices into categories based on technical features such as stress loading, positional imaging, and the configuration of the scanner bore. Although it is likely that our scheme may not anticipate all possible modifications of existing devices or future technical advances, we feel that, currently, it provides a practical way of categorizing a diverse group of imaging technologies. Although the proposed classification scheme is based on three device features (open-bore design, patient positioning and imaging under loading stress), it should be noted that additional features, such as the ability to obtain dynamic/kinematic imaging or the device field strength, could also be considered as part of this classification scheme. For example, imaging under stress loading using axial loading devices can be performed both in conventional (high field strength) and open (typically, low field strength) MRI scanners; thus, field strength can be used to further subclassify uses of simulated gravity.

Regardless of any special features of each specific diagnostic technology, the assessment of diagnostic tests typically follows a stepwise approach,114 progressing from the establishment of technical and clinical validity, to the assessment of the impact of the test on physicians’ diagnostic thinking and therapeutic decision making, as well as clinical outcomes. Finally, a global assessment of the test from a societal perspective can be performed. This stepwise assessment approach, as described by Fryback and Thornbury,30 is also applicable to stress-loading MRI (Figure 6). In the next section, we discuss specific approaches to future research, broadly following this scheme.

Figure 6 Application of the conceptual framework proposed by Fryback et al. for evaluating the efficacy of diagnostic imaging for researchers and policymakers30

In this framework, patients undergoing MRI imaging with novel technologies may experience adverse events associated with the imaging process and (potentially) obtain additional diagnostic/prognostic/ monitoring information from the imaging performed under stress loading. This information may impact diagnostic or therapeutic thinking. Test-directed therapies impact patient outcomes directly, including pain and other clinical symptoms, quality of life, and clinical events. Overall, the impact of imaging under stress-loading on the healthcare system can be captured by assessing the cost-effectiveness of integrating these tests into clinical practice.

Figure 6 depicts a conceptual framework, based on the scheme proposed by Fryback et al., for evaluating the efficacy of diagnostic imaging for researchers and policymakers. The graph describes a stepwise approach, progressing from the establishment of technical and clinical validity, to the assessment of the impact of the test on physicians’ diagnostic thinking, therapeutic decision making, and clinical outcomes. Finally, a global assessment of the test from a societal perspective can be performed. Beginning with patients with musculoskeletal pain where positional MRI may be considered, evaluation proceeds (depicted as arrows) through five levels: Level 1 = Visualization of weight-bearing anatomical changes; Level 2 = Diagnostic accuracy efficacy; Level 3 = Diagnostic impact; Level 4 = Therapeutic impact; Level 5 = Surgical or other clinical outcomes. Level 6, labeled technology diffusion and cost of weight-bearing MRI, spans all other levels. Evaluation of adverse events associated with testing is denoted as occurring prior to Level 1, and adverse effects of test-directed treatments prior to Level 5.

Based on this conceptual framework, findings from the evidence map, and input from key informants (KIs), we suggest that future research and policy on emerging MRI technologies under loading stress include the following:

- Addressing the methodological issues in study design and analysis that are prevalent in the existing literature so that future studies can better evaluate the reliability and diagnostic accuracy of novel MRI technologies. (Fryback Levels 1 and 2).
- Assessing the impact on diagnostic thinking and therapeutic decision making of stress-loading MRI technologies using clinically relevant patient outcomes (Fryback Levels 3 and 4).
- Assessing impact of the most promising of these technologies on patient outcomes through prospective observational studies or RCTs. (Fryback Level 5).
- Creating special procedure codes for imaging using different MRI devices that will facilitate future research and policy decisions regarding these technologies.

These suggestions are expounded upon in further detail below.

## Methodological Considerations for Future Studies of Diagnostic Accuracy

Based on our review of the study designs and methods utilized in the published studies (across diverse clinical applications, and different MRI technologies and configurations), here we briefly discuss several crosscutting methodological issues that we have identified. Although some issues are unique to each device and clinical application, several apply more generally and have been summarized below (Table 7).Adherence to these principles would facilitate the assessment of the reliability and clinical accuracy of the different imaging modalities.

Table 7 Common methodological issues and proposed solutions

Limitations in the existing evidence base | Proposed solutions
Epidemiological issues
Case-control designs were often used to assess the ability of devices to identify differences between affected and unaffected individuals. | Although case-control designs are appropriate for identifying anatomic or physiologic differences between disease and healthy individuals, they have been shown to result in biased estimates of diagnostic accuracy.115 Studies assessing diagnostic accuracy should instead aim to enroll patients representative of the spectrum of disease typically seen in clinical practice.
Detailed inclusion and exclusion criteria were not reported in the majority of studies. This was particularly evident regarding the selection of “healthy control individuals.” | When a case-control design is appropriate, the selection of control participants representative of the study base is crucial. Serious bias can arise if the control group is not representative of the population that gave rise to the cases.116 Future studies should provide details about the study base and sampling methods employed to select cases and controls.
Details of the study design were often not reported. | General principles for the design of studies of imaging tests include the use of an appropriate reference standard, adequate description of the index and reference tests, blinded interpretation of test results, and independence of the index and reference standard tests.117
Sample sizes were typically small (median number of cases: 26, 25th–75th percentile: 17, 41). Because statistical power to test hypotheses depends on sample size, existing studies do not allow accurate conclusions to be drawn. | Future studies should be larger, ideally designed based on power calculations, to be able to reliably detect plausible effect sizes and provide precise estimates of diagnostic accuracy.116
For studies of diagnostic accuracy, outcome definitions were often unclear, as were the means of ascertaining them. | Future studies should report the definitions of outcomes and ascertainment methods. For subjective outcomes it is best to obtain outcome assessment by multiple raters, report their expertise, and perform a formal test of rater agreement.118
For studies assessing clinical outcomes, blinding to test results was frequently not reported or not performed. | Since the interpretation of imaging tests is frequently subjective, assessments should preferably be performed in a blinded fashion to avoid bias.117,119
Analytical aspects
Multiple anatomic regions or pathologic lesions were present in each patient. For example, in studies of rheumatoid arthritis, multiple erosions could be present in multiple bones in a single patient. Similarly, in studies of lumbar spine imaging, multiple spinal levels might be assessed. Typically, analyses ignored the natural “clustering” of multiple observations within individuals. | Methods that ignore “clustering” can result in biased and spuriously precise estimates of sensitivity and specificity. Future studies should use methods that account for within patient clustering. Only rarely were more appropriate methods, such as multilevel modeling or other correlated data-analysis methods, employed.93,95
Sample size determination was rarely based on prospective power calculations.116 | Power calculations would ensure that studies enroll enough patients to be able to reliably test their hypotheses. For simple statistical tests, such as the comparison of two means or proportions, power calculations are easy to implement in most commercial statistical packages. For more complicated designs expert input may be required.
In most cases the analytic validity of imaging tests was unclear or not established. This was particularly evident for studies of stress-loading MRI, where a reference test was often not available.120–123 When comparing measurements or clinical findings obtained using different MRI devices, correlation or regression methods were often used to demonstrate “congruence” between technologies. C correlation and regression are inappropriate for assessing agreement between measurements.124 | Future studies should use standardized and replicable procedures for stress-loading MRI, and assess the test agreement between stress-loading MRI and an independent imaging modality. Studies should use appropriate methods for assessing agreement, both for continuous and categorical outcomes.124–126
In comparative studies of imaging tests, in the absence of a gold standard, authors frequently and arbitrarily selected one of the tests as a “reference” and proceeded to calculate sensitivity and specificity for the other test, that is, treating it as the “index test.” It was common that the “reference test” in one study was considered as the “index test” in another. It is well appreciated that sensitivity and specificity estimates are biased when the gold standard is tarnished. | When no gold standard test is available, it is preferable to use methods that account for its absence (i.e., treat the prevalence as an additional parameter to be estimated). Such methods are available under both frequentist and Bayesian frameworks.121,122,127,128

## Assessing Impact on Diagnostic Thinking and Therapeutic Decisionmaking

Assessing the impact of imaging tests on diagnostic thinking and therapeutic decisionmaking is vital as this information allows direct inference on the effects of diagnostic tests on patient outcomes. Commonly used methods for assessing this impact are based on questionnaire evaluation of the proportion of cases in a patient cohort for whom the imaging test was considered “helpful” for diagnosis or treatment choice. More rigorous approaches are to assess the extent to which new information (from the diagnostic test) modifies the physician’s perception of a specific clinical case. For example, one can compare the diversity in the probability distribution of potential diagnoses before and after test information is obtained (i.e. quantify the change in entropy of the probability distribution of differential diagnoses induced by the test information). A good test allows clinicians to “narrow down” the diagnostic possibilities (i.e., reduce the diversity in the distribution of differential diagnoses).129 However, there is an inherent subjectivity in these approaches, most available methods do not take into account diagnostic accuracy (since the “true” diagnosis typically remains unknown after the test is performed, and this is most often ignored in the above mentioned calculations), and impact on physician’s thinking does not necessarily translate to impact on clinical outcomes.130 If they are to be informative, studies of impact on diagnostic and therapeutic thinking need to be conducted in representative patient populations and diagnostic/treatment settings, preferably after the diagnostic accuracy of the tests of interest has been established.

## Assessing Impact on Patient Outcomes in Observational Studies and RCTs

Ultimately, we need to know whether the use of a particular diagnostic test results in better outcomes for patients. The most internally valid evidence regarding the impact of a diagnostic test on patient outcomes can be obtained from randomized controlled trials (RCTs) of alternative testing strategies. Several randomized designs have been proposed for diagnostic, prognostic, and predictive tests and can be applied to weight-bearing or stress-loading MRI. Although RCTs can produce robust evidence on the impact of diagnostic tests on clinical outcomes and costs, they may not be the best initial strategy in this case.131 A test affects patient outcomes mainly by influencing diagnostic thinking and therapeutic choices.132 In addition, an imaging test can be used as a replacement test (e.g., weight-bearing MRI instead of conventional MRI), an add-on test (e.g., axially-loaded MRI following conventional MRI) or a triage test (e.g., weight-bearing or axially loaded MRI to determine if myelography is necessary).132 In each case, a different threshold for test positivity can be used. Each permutation of different tests, test combinations, and test thresholds represents a candidate test-and-treat strategy. It is often infeasible or inefficient to assess all potential strategies in RCTs. However, a staged approach using observational studies to identify the best most promising technologies, may be possible.132,133 Instead, diagnostic accuracy can be assessed in the clinical context of interest using observational designs, and then, based on the performance of the tests, a decision can be made on whether an RCT of testing versus no testing (or comparing alternative tests) is necessary or whether the test can be implemented with no further study. This decision mainly depends on the relative accuracy of the diagnostic tests of interest and the availability of effective treatments for patients with an established disease diagnosis.133 Lord et al. have proposed a framework for diagnostic test evaluation both by primary research studies and by systematic Technology Assessments.132 In addition to these methods, decision modeling methods can be used to evaluate the potential long-term impact of diagnostic tests on clinical outcomes.134,135

With these considerations in mind, the most practical research strategy may be to explore the diagnostic accuracy (sensitivity and specificity) of different weight-bearing and stress-loading MRI approaches in well-designed cohort or case-control studies. An appropriate reference standard, such as surgical findings or myelography, may be available in some cases but require the patient to undergo invasive procedures. In other cases where a gold standard is lacking, specialized statistical methods can be used as described above. To be clinically useful and informative, observational studies should enroll patients representative of those seen in clinical practice, and limit verification and other biases.136,137 Such studies should be relatively feasible, given the high prevalence of the conditions of interest (musculoskeletal disease), the familiarity of clinicians and patients with MRI, and the lack of known harms related to MRI imaging. When RCTs are contemplated, strategies to increase efficiency such as only randomizing patients for whom conventional and emerging MRI technologies suggest different diagnoses (i.e., patients with discrepant imaging findings), should be considered.136

## Creating Separate Procedure Codes for Special MRI Procedures

Based on our searches of the grey literature and KI input, there appears to be no special procedure code for stress-loading MRI, and at least in some cases, stress-loading MRI may have been associated with increased health care costs (due to multiple billings for the same imaging session). It is possible that separate procedure codes may increase transparency and allow better monitoring of the MRI examinations performed. Separate procedure codes would also facilitate future population-level research on the clinical use of stress-loading MRIs.