# Methods

## Guiding Questions

This Technical Brief aims to answer the following Guiding Questions that were developed in collaboration with the Agency for Healthcare Research and Quality and input from Key Informants (KIs). The terminology used in the guiding questions to describe magnetic resonance imaging (MRI) technologies that were included in this Technical Brief was changed from “positional MRI” to current “stress-loading MRI” after the literature review determined that stress-loading MRI more accurately described the principle underlying the technologies of interest. Throughout the report, we use “stress-loading MRI” or “MRI technologies under loading stress” to cover all MRI modalities and applications that allow imaging under stress-loading or weight-bearing conditions, which include positional or upright MRI devices.

### Guiding Question 1

What are the operating principles of stress-loading MRI, and what are the potential benefits and harms associated with its use?

a. What are the postulated advantages and disadvantages of stress-loading MRI testing compared to contemporary imaging alternatives?
b. To which populations and for what indications might such testing apply?
c. Is stress-loading MRI being proposed as a replacement, triage, or add-on test?
d. What are the potential safety issues and harms of stress-loading MRI technologies?

### Guiding Question 2

What is the current availability and cost of stress-loading MRI testing, and what are the special requirements that stress-loading MRI facilities have to fulfill?

a. Who are the current (major) manufacturers of stress-loading MRI machines? What is the current Food and Drug Administration (FDA) clearance status of these stress-loading MRI machines?
b. Approximately how many and of what kind are facilities currently providing stress-loading MRI testing in the United States? Do they use the technology mainly for routine work or for research purposes? What additional equipment or technical resources are needed in order to operate stress-loading MRI compared with standard MRI?
c. What kinds of training, certification, and staffing are required to operate stress-loading MRI or interpret its images?
d. What is the cost of imaging with stress-loading MRI technology as compared to other imaging alternatives?

### Guiding Question 3

What published studies have reported on the diagnostic performance, efficacy/effectiveness, or safety of stress-loading MRI? Organize them according to the Fryback and Thornbury scheme,30 and provide a synthesis of the following information as applicable:

1. Groups of patients enrolled
2. Type of stress-loading MRI used
3. Study design and size
4. Role of the test in patient management
5. Clinical setting where stress-loading MRI testing was performed
6. Outcomes assessed
7. Adverse events, harms and safety issues reported
8. Comparators used (applicable only to comparative studies)
9. Length of followup (applicable only to longitudinal studies)

### Guiding Question 4

What is the projected uptake of stress-loading MRI technology in the near future? What are the potential areas for future research that are most meaningful given the current state of the evidence and the projected uptake of the technology?

a. Are there indications that stress-loading MRI technologies will be widely used in the near future?
b. What are possible areas of future research?

To address these questions we used a combination of literature review, KI interviews, grey literature, and evidence map(i.e., a systematic description of the characteristics of the published studies) to answer the guiding questions.

## Identification of Key Informants and Interviews

In order to gain an understanding of the most important clinical uncertainties, patterns of use, and technical details about this new and rapidly evolving technology, we interviewed a selected number of KIs. When identifying KIs, we aimed for a diverse and representative group that was likely to generate a broad range of perspectives on MRI technology. Eight KIs were chosen, consisting of a director of a public Health Technology Assessment program (public payer), a medical director of a private insurance payer, a neuro-radiologist, an orthopedic surgeon, a radiologist whose clinical expertise and research are focused on the use of stress-loading positional MRI, two business managers with research backgrounds in MRI currently employed by two different MRI device manufacturers, and a patient with chronic low-back pain. We did not use a formal method to identify KIs, such as random sampling from a large pool of candidates for reasons of timeliness and feasibility.

At the beginning of the project, two group KI calls were conducted that included all KIs except for the two industry business managers due to conflicts of interest. These two calls helped us to finalize our literature search strategy and guiding questions. To better understand the context and application of the MRI technologies, we then performed one-on-one interviews with each KI (with the exception of the patient), and tailored our interview questions to the expertise and unique perspective of each KI (e.g., public or private insurance payer, clinicians, or MRI device manufacturers). Recordings were made of each interview for the purpose of accurate transcription, and then destroyed following the composition of interview summaries. Interview summaries were sent to each respective KI to confirm their accuracy. We did not obtain further input from the patient representative as we did not have additional patient-specific questions.

## Grey Literature Search

We performed an Internet search for keywords to identify relevant MRI devices and their manufacturers. Search terms included, but were not limited to, “positional MRI,” “upright MRI,” “stand up MRI,” “weight bearing MRI,” and “axial loading MRI.” We also searched MRI manufacturers’ Web sites for additional information. These searches yielded background information (primarily in the form of company brochures), and helped us formulate interview questions for KIs. Additionally, we searched the FDA Center for Devices and Radiological Health database to identify major MRI manufacturers and obtain FDA clearance status of relevant MRI devices. To identify potential harms of relevant MRI devices, we queried the FDA Manufacturer and User Facility Device Experience (MAUDE) database using specific device brand names, manufacturers, or the product code “LNH.” Although the MAUDE database has several limitations because it collects information based on reporting from diverse sources, including clinicians, patients, user facilities or manufacturers, it can still provide useful data on rare or unexpected adverse events.31 We also searched for private insurance (e.g., Blue Cross Blue Shield, Aetna, and Anthem) reimbursement policies for positional (weight-bearing) MRI, and ClinicalTrials.gov for relevant ongoing studies using the same terms as our primary Internet search. KIs provided additional relevant conference abstracts or book chapters, as well.

To assess the worldwide patterns of growth in MRI availability and utilization, we used the latest version of health data from the Organization for Economic Co-Operation and Development (OECD) to obtain estimates of the number of MRI scanners per million population in OECD countries and the number of MRI scans conducted per 1,000 population annually.12

## Building an Evidence Map

An evidence map aims to summarize the extent and distribution of evidence in a broad clinical area. A systematic and replicable, but non exhaustive, methodology is employed to efficiently appraise the available evidence on a topic of interest as well as identify major knowledge gaps.32 The goal is to provide investigators with information about the type and amount of research available, the characteristics of that research, and the topics where a sufficient amount of evidence has accumulated for synthesis. In contrast to systematic reviews, which are lengthy and labor intensive, evidence mapping is a cost-effective method to inform users of the current state of research findings that could be used to generate hypotheses, inform ongoing research, and identify research gaps.

### Published Literature Search

Our search strategy employed the National Library of Medicine’s Medical Subject Headings (MeSH) keyword nomenclature developed for MEDLINE. We searched for studies that used MRI with weight-bearing or stress-loading protocols in patients with musculoskeletal conditions, published from 1975 to September 2010. We combined MeSH or search terms for MRI, terms relevant to weight-bearing or loading devices and techniques (e.g., dynamic, vertical, upright, stand*, seat*, open, position*, weight bearing, axial$ or load$), and terms relevant to patient populations (e.g., spinal osteophytosis, intervertebral disk displacement, spinal stenosis, spondylolisthesis, thoracic vertebrae, or whiplash injuries). We expanded our search to include dedicated extremity MRI research by adding the terms “extremity specific” or “dedicated.” The details of our search strategies are listed in Appendix A. Our KIs provided additional relevant citations.

Three reviewers jointly screened the first 300 citations to ensure that screening criteria were well understood and applied uniformly. Thereafter, the same investigators screened non overlapping sets of the remaining citations. Citations not considered relevant by a single investigator were screened independently by a second investigator to increase the sensitivity of the screening process. We retrieved full-text articles for all citations at least one reviewer considered potentially relevant. Three reviewers independently reviewed articles.

### Definitions and Study Eligibility Criteria

Based on preliminary searches and KI input, we identified several configuration or imaging acquisition features that we considered relevant to produce an accurate description of the capabilities and limitations of the diverse MRI imaging systems designed to improve accuracy by imaging joints under physiologic conditions. We focused on three distinct features of these emerging MRI technologies and applications: (1) the ability to choose alternative positioning, (2) the ability to perform imaging under stress-loading conditions; and (3) having an open or semi-open configuration. Specific devices may incorporate one or more of these features. In the Findings section, we describe the classification scheme that we developed based on these features to categorize the different MRI devices that we reviewed and the operational definitions that we employed for this purpose. A Venn diagram presenting our proposed operational classification is presented in Figure 3 (see the Findings section, Description of Stress-Loading MRI subsection.)

Although the focus of this report is stress-loading MRI, input from our KIs suggested that we expand our literature search to include studies of small bore, dedicated extremity MRI despite the absence of stress-loading applications, due to the technology’s potential for rapid development and diffusion. We discovered a substantial literature available for dedicated extremity MRI, but because the technical features of these devices were determined to be distinct from those of the other technologies we considered, we were not able to integrate it meaningfully into the current report. However have presented our search results for dedicated extremity MRI in Appendix F and refer to these devices in the main text of the report for comparison purposes.

We included published studies of any design with primary data on the application of eligible MRI imaging methods in at least 10 patients (or a total of 10 cases and controls for case-control studies) with any musculoskeletal condition except those affecting the temporomandibular joint, since stress loading is not a relevant approach for that joint. We did not consider studies of dynamic MRI (i.e., MRI while the joint is in movement), unless imaging was obtained under stress-loading conditions. Studies exclusively recruiting healthy individuals were excluded. We did not consider narrative reviews, editorials, letters to the editor, or other publications not reporting primary research findings. We did not consider studies published only in abstract form.

### Data Extraction

Data were extracted from studies considered relevant in categories A through D, as defined in Findings (see the Description of Stress-Loading MRI subsection). Briefly, category A included open MRI scanners that allow obtaining views under different positions under stress loading; category B included devices that allow imaging under stress loading in different positions but have a closed bore configuration; category C included devices for stress loading under conventional (supine) positioning in a closed scanned; and category D included devices with an open configuration that allow imaging under stress loading in a conventional (supine position). Extracted data included: publication information (first author name, journal, and year of publication), study design, condition studied, study size and clinical setting, patient selection criteria and outcomes assessed. We also recorded data relevant to the specific weight-bearing or loading technique as well as the technical specifications of the respective MRI device.

For all comparative studies of two diagnostic tests (one of which must have involved weight-bearing or stress-loading MRI), we extracted additional information on the comparators, outcomes, and key findings.

We used Epidata version 3.1 (EpiData Association, Odense Denmark)33 to extract information on items of interest in an electronic form (Appendix B). When possible, we gave examples or definitions for items of interests in the data extraction form to minimize the variation in interpretation. Prior to extraction, we performed a series of calibration exercises to ensure consistency and accuracy of data extraction across investigators.

### Data Presentation and Analysis

Our findings are presented in the order of guiding questions. We summarized findings from grey literature searches and KI interviews qualitatively. We generated tables and graphs to summarize information relevant to Guiding Question 3 (Evidence Map). Based on the data items extracted (see Data Extraction section, above), we calculated summary descriptive statistics over the eligible studies, such as proportions (e.g., of studies with a specific characteristic), or medians and interquartile range (e.g., for study sample sizes), as applicable.34 We graphically presented quantitative data using line graphs for growth curves and weighted scatter plots to summarize the sample sizes, study designs, and specific MRI devices investigated in the studies we reviewed. Statistical analyses and graphs were generated using Stata version 11.1/SE (Stata Corp., College Station, TX).

To determine whether particular findings or research groups are over represented in the literature, we identified studies that had any overlap in author lists by cross-checking author names and institutions across the studies we reviewed. Studies defined as “conducted by the same research teams” were those that had any coauthors in common. Undirected graphs depicting groups of studies that were conducted by the same research team were generated.

Based on our overview of the literature and generally accepted statistical and epidemiological principles, we provide recommendations for improving study design and analyses in studies of novel imaging technologies.