# Appendixes

Appendix A Search Strategy

Appendix B Data Extraction Form

Appendix C Examples of Commercially Available Devices That Allow MRI Under Weight-Bearing or Stress-Loading Conditions

Appendix D Shared Authorship Patterns in Studies of Weight-Bearing or Stress-Loading MRI

Appendix E Comparative Studies of Diagnostic Tests

Appendix F Dedicated Extremity MRI Devices