# Dedicated Extremity MRI Devices

Our literature searches as well as Key Informant (KI) feedback indicated that dedicated extremity magnetic resonance imaging (MRI) devices could be considered as part of the Technical Brief due to a number of possible advantages over conventional MRI devices, such as not requiring the patient’s body to be placed in the scanner’s bore. The theoretical benefits and drawbacks of these “semi-open” devices are discussed in the Description of Stress-Loading MRI subsection of the Findings section of the main report.

Based on our review of the published literature, it became apparent that extremity dedicated scanners are typically not used to obtain imaging under weight-bearing or stress-loading conditions. Specifically, out of a total of 38 relevant studies using a dedicated MRI scanner (including 2 studies enrolling healthy subjects only), only one used mechanical modifications to obtain images under loading conditions among healthy subjects.1 As this study enrolled only healthy subjects, we did not include it in our evidence map. The literature on non-stress-loading applications of dedicated extremity MRI studies appears to be rather extensive and includes several comparative studies and a randomized controlled trial; therefore, we decided to present a summary of the relevant studies. Here, we briefly summarize the clinical settings, diseases, and comparisons reported in the 36 published applications of non-stress-loading dedicated extremity MRI. We present below a table of detailed information regarding the populations, specific extremity MRI devices, comparators, and outcomes assessed in each study.

Appendix Table Studies of Dedicated Extremity MRI Devices

Author, year (Country) [PMID] Study Design | N enrolled | Patient population | Setting | E-MRI [Manufacture] (Field strength) | Comparison | MR Imaging location | Outcome (assessment)
Rheumatoid arthritis
Xie, 2008^40^ (Canada) [19032820] Case-control | 39 | Cases: RA | Cases: rheumatology clinics | OrthOne [ONI Medical Systems] (1.0T) | Cases vs. controls | MCP joints; wrist | Synovitis, bone edema, bone erosion (OMERACT RAMRIS scoring)
Xie, 2008^40^ (Canada) [19032820] Case-control | 41 | Controls: no joint disease | Controls: community | OrthOne [ONI Medical Systems] (1.0T) | Cases vs. controls | MCP joints; wrist | Synovitis, bone edema, bone erosion (OMERACT RAMRIS scoring)
Savnik, 2001^28^ (Denmark) [11419149] Cross-sectional | 103 | RA | NR | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | High-field MRI - Gyroscan ACS-NT [Philips, Best, Netherlands] (1.5T) | Wrist; MCP and IP joints | Synovial membrane volume, joint enhancement, joint effusion, bone edema, bone erosions (visual analysis)
Yoshioka, 2006^41^ (Japan) [16456819] Case-control | 13 | Cases: Suspected early RA, RA; soft-tissue swelling | NR | Compact MRI [originally developed by investigators] (0.21T) | Cases vs. controls Among cases only, also comparison to plain radiographs | Hand; wrist | Radiologists’ routine reading
Yoshioka, 2006^41^ (Japan) [16456819] Case-control | 13 | Controls: no clinical symptom of arthritis | NR | Compact MRI [originally developed by investigators] (0.21T) | Cases vs. controls Among cases only, also comparison to plain radiographs | Hand; wrist | Radiologists’ routine reading
29, 2000 (Germany) [10663314] Cross-sectional | 10^a^ | Patients with ACL injuries who are able to hyperextend the uninjured knee. | NR | Artoscan [Esaote Biomedica, Genoa, Italy] (0.18T) | None. | Knee | Only anatomic measurements
Duer-Jensen, 2008^42^ (Denmark) [17984195] Case-control | 15 | Cases: RA | Single academic hospital | 2 E-MRI scanners were used: Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) MagneVu MV1000 [MagneVu, Carlsbad, CA] (0.2T) | Plain radiographs. The Artoscan E-MRI results were considered as the gold standard and the MagneVu E-MRI and plain radiographs were treated as index tests to calculate diagnostic accuracy. | Hand ; wrist | Synovitis, bone edema, bone erosion (OMERACT RAMRIS scoring)
Duer-Jensen, 2008^42^ (Denmark) [17984195] Case-control | 4 | Controls: healthy individuals with no signs or symptoms of joint disease | Single academic hospital | 2 E-MRI scanners were used: Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) MagneVu MV1000 [MagneVu, Carlsbad, CA] (0.2T) | Plain radiographs. The Artoscan E-MRI results were considered as the gold standard and the MagneVu E-MRI and plain radiographs were treated as index tests to calculate diagnostic accuracy. | Hand ; wrist | Synovitis, bone edema, bone erosion (OMERACT RAMRIS scoring)
Cimmino, 2003^43^ (Italy) [12746893] Case-control | 36 | Patients: RA | 10 outpatients in remission (per ACR criteria) and 26 patients with clinical involvement of at least one wrist either hospitalized in a university rheumatology clinic or as outpatients. | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | RA patients were classified into 3 groups based on disease severity. Imaging findings between the 3 disease groups and the controls were compared. Imaging parameters were also correlated with clinical outcomes and laboratory measurements. | Wrist | Association of imaging parameters with disease presence and severity. Correlation of imaging parameters with clinical and laboratory measurements. (clinical and laboratory findings were masked during image processing)
Cimmino, 2003^43^ (Italy) [12746893] Case-control | 5 | Controls: healthy volunteers | 10 outpatients in remission (per ACR criteria) and 26 patients with clinical involvement of at least one wrist either hospitalized in a university rheumatology clinic or as outpatients. | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | | Wrist
Cimmino, 2005^24^ (Italy) [15987474] Case-control | 15 | Cases: Psoriatic arthritis | Single academic rheumatology clinic, both inpatient wards and outpatient clinics | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Imaging findings between the 3 disease groups and the controls were compared. Imaging parameters were also correlated with clinical outcomes and laboratory measurements. | Wrist | Association of imaging parameters with disease presence. Correlation of imaging parameters with clinical and laboratory measurements. (Image assessment was performed blind to the clinical and laboratory findings)
Cimmino, 2005^24^ (Italy) [15987474] Case-control | 49 | Cases: RA, “consecutive” | Single academic rheumatology clinic, both inpatient wards and outpatient clinics | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Imaging findings between the 3 disease groups and the controls were compared. Imaging parameters were also correlated with clinical outcomes and laboratory measurements. | Wrist
Cimmino, 2005^24^ (Italy) [15987474] Case-control | 30 | Cases: RA, matched for age, disease duration and number of involved joints with the psoriatic arthritis group (9 patients overlapped with the group of consecutive RA patients) | Single academic rheumatology clinic, both inpatient wards and outpatient clinics | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Imaging findings between the 3 disease groups and the controls were compared. Imaging parameters were also correlated with clinical outcomes and laboratory measurements. | Wrist
Cimmino, 2005^24^ (Italy) [15987474] Case-control | 8 | Controls | Single academic rheumatology clinic, both inpatient wards and outpatient clinics | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Imaging findings between the 3 disease groups and the controls were compared. Imaging parameters were also correlated with clinical outcomes and laboratory measurements. | Wrist
Duer-Jensen, 2009^44^ (Denmark) [18718987] Case-control | 20 | Cases: RA | NR | 2 E-MRI scanners were used: Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) MagneVu MV1000 [MagneVu, Carlsbad, CA] (0.2T) | CT and plain radiographs All 4 tests were performed in cases and controls | Hand; wrist | Bone erosion detection (OMERACT RAMRIS scoring for MRI)
Duer-Jensen, 2009^44^ (Denmark) [18718987] Case-control | 5 | Controls: healthy individuals | NR | 2 E-MRI scanners were used: Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) MagneVu MV1000 [MagneVu, Carlsbad, CA] (0.2T) | CT and plain radiographs All 4 tests were performed in cases and controls | Hand; wrist | Bone erosion detection (OMERACT RAMRIS scoring for MRI)
Ejbjerg, 2005^45^ (Denmark) [15650012] Case-control | 37 | Cases: RA | Single academic hospital | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | High-field MRI -Impact [Siemens] (1.0T) and plain radiographs All tests were performed on cases and controls; in 10 patients and 10 controls a preliminary study to determine the optimal imaging setting for the E-MRI was performed. Plain radiographs were only used for bone erosion detection. | Hand; wrist | Synovitis, bone edema, bone erosion (OMERACT RAMRIS definitions)
Ejbjerg, 2005^45^ (Denmark) [15650012] Case-control | 28 | Controls: healthy individuals | Single academic hospital | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | | Hand; wrist | Synovitis, bone edema, bone erosion (OMERACT RAMRIS definitions)
Freeston, 2007^46^ (UK) [17666445] Cross-sectional | 15 | RA | NR | MagneVu MV1000 [MagneVu, Carlsbad, CA] (0.2T) | High-field MRI-Gyroscan ACS-NT [Philips, Best, Netherlands] (1.5T) and plain radiographs | Hand; wrist | Bone erosion detection (OMERACT definition of erosion)
Gaylis, 2007^20^ (USA) [17694258] Retrospective longitudinal | 48 | Infliximab-treated RA | Single rheumatology practice | MagneVu 1000 [MagneVu, Carlsbad, CA] (0.2T) | Plain radiographs | Hand; wrist | Baseline bone erosion detection, monitoring of response to treatment (Two radiologists blinded to the patients’ clinical status used a system to classify erosions as small, moderate or large. They also ascertained “regression” versus “stability” of the lesions)
Tajiri, 1999^47^ (Japan) [10406343] Case-control | 8 | Cases: RA with symptomatic sublaxation of the distal ulna | NR | Artoscan [Esaote Biomedica, Genoa, Italy] (0.18T) using a custom-made positioning device to obtain scans of the upper extremity during rotation | Cases vs. controls regarding motion during rotation | Distal radioulnar joint | Images were analyzed with regard to rotation, distance between radius and ulna, and range of motion.
Tajiri, 1999^47^ (Japan) [10406343] Case-control | 5 | Controls: asymptomatic volunteers | NR | Artoscan [Esaote Biomedica, Genoa, Italy] (0.18T) using a custom-made positioning device to obtain scans of the upper extremity during rotation | Cases vs. controls regarding motion during rotation | Distal radioulnar joint | Images were analyzed with regard to rotation, distance between radius and ulna, and range of motion.
Roemer, 2005^48^ (USA) [15633060] | 23 | Suspected or proven osteoarthritis of the knee | Participants in the MOST epidemiological study | OrthOne [ONI Medical Systems, Wilmington, MA] (1.0T) | Different imaging sequences | Knee | Grading of osteoarthritis (two musculoskeletal radiologists blinded to participant data read all MRI scans)
Schiff, 2007^49^ (USA) [17519063] Cross-sectional | 300^b^ | Clinical diagnosis of RA | Single community-based rheumatology practice | MagneVu MV1000 [MagneVu, Carlsbad, CA] (0.2T) | Comparison of clinical and laboratory findings and treatment-related data (change in therapeutic regimen) between “MRI positive” and “negative” patients. Multivariate modeling to identify predictors of a “positive” MRI scan. | Hand; wrist; feet | Marrow edema, subhondral cysts, erosions, joint space narrowing (four radiologists interpreted the exams, each scan was reviewed by a single rater)
Segal, 2009^50^ (USA) [19533741] Nested case-control | 30 | Cases: incident symptomatic knee osteoarthritis | Participants in the MOST epidemiological study | OrthOne [ONI Medical Systems, Wilmington, MA] (1.0T)^c^ | Cases vs. controls (baseline MRI data were used to develop contact stress models to predict the development of incident osteoarthritis by 15 months of followup) | Knee | Prognosis of osteoarthritis development expressed as prognostic accuracy (computational stress analysis of the baseline MRI scan was used to predict the development of incident osteoarthritis)
Segal, 2009^50^ (USA) [19533741] Nested case-control | 30 | Controls: randomly selected individuals from the same cohort | Participants in the MOST epidemiological study | OrthOne [ONI Medical Systems, Wilmington, MA] (1.0T)^c^ | Cases vs. controls (baseline MRI data were used to develop contact stress models to predict the development of incident osteoarthritis by 15 months of followup) | Knee | Prognosis of osteoarthritis development expressed as prognostic accuracy (computational stress analysis of the baseline MRI scan was used to predict the development of incident osteoarthritis)
Taouli, 2004^51^ (USA) [15039167] Cross-sectional | 18 | RA | Single academic rheumatology center | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | High-field MRI-Signa [General Electric medical Systems] (1.5T) and plain radiographs. Scores based on the different imaging methods were compared as continuous measurements. | Hand; wrist | Bone erosions, joint-space narrowing and synovitis. (Two independent reviewers assigned Genant-modified Sharp radiographic scores based on plain radiographs. A modification of the system was used for MRI)
Lindegaard, 2001^52^ (Denmark) [11454641] Case-control | 25 | Cases: RA | Single academic rheumatology clinic | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Clinical examination and plain radiographs. Correlation of imaging scores with laboratory findings. | Hand; wrist | E-MRI: Detection of bone erosions (visual assessment), grading of synovitis (using a semi-quantitative system). Plain radiographs: presence and number of bony erosions (assessed by an independent investigator blinded to the clinical and E-MRI findings). Clinical exam: joint swelling and tenderness (assessed by a rheumatologist based on EULAR criteria).
Lindegaard, 2001^52^ (Denmark) [11454641] Case-control | 3 | Controls: healthy individuals | Hospital staff | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Clinical examination and plain radiographs. Correlation of imaging scores with laboratory findings. | Hand; wrist
Lindegaard, 2006^53^ (Denmark) [16540550] Longitudinal study^d^ | 24^e^ | RA | Single academic clinic | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Plain radiographs. Radiographs and E-MRI assessments were performed at baseline, 6 and 12 months to assess disease course and response to treatment. Findings were correlated with clinical and laboratory results. | Hand; wrist | Monitoring of response to treatment based on number of erosions, bone edema, tenosynovitis (For E-MRI: OMERACT scoring by a radiologist blinded to clinical and radiographic findings; for radiographs: Larsen scores and presence of bone erosions)
Eshed, 2006^54^ (Germany) [16882591] Cross-sectional | 38 | RA | Single center rheumatology outpatient clinic | C-scan [Esaote Biomedica, Genoa, Italy] (0.2T) | Image quality (contrast-to-noise and signal-to-noise ratios) and the presence of synovitis were compared between E-MRI using a single vs. a double dose of contrast-enhancing material. | Hand; wrist | Image quality parameters and synovitis scoring (OMERACT RAMRIS score)
Crues, 2004^55^ (USA) [15088291] | 132 of whom 125 were successfully imaged | Inflammatory arthritis (95% had RA and 5% had joint symptoms in the setting of psoriasis) | Single academic center | MagneVu MV1000 [MagneVu, Carlsbad, CA] (0.2T) | Plain radiographs | Hand; wrist | Erosions detected by each imaging modality and intra-and inter-rater agreement (two raters reviewed all scans)
Drapé, 1998^56^ (France) [9646792] Cross-sectional | 43 | Knee osteoarthritis | Single center | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Arthroscopic evaluation | Knee | French Society of Arthroscopy scores and grades (qualitative and quantitative assessment by a single arthroscopist blind to the patient’s identity and MRI findings; MRI assessment based on qualitative and quantitative assessment by two radiologists blind to the patient’s identity and arthroscopic findings)
Knee, shoulder, elbow, foot, ankle pathology
Pessis, 2003^57^ (France) [12744942] Prospective, longitudinal study | 20 | Symptomatic tibiofemoral osteoarthritis with indication for arthroscopic joint lavage | Single academic center | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Plain radiographs (weight-bearing fully extended and flexed knee) Arthroscopy performed immediately after the E-MRI All tests were repeated 1 year after the base-line examination. | Knee | For arthroscopy severity of cartilage breakdown, chondropathy. For E-MRI: articular cartilage lesions, bone marrow edema, subchondral bone abnormalities. (all tests were interpreted by a investigators unaware of the patient identity and the chronology of the investigations)
Zlatkin, 2004^58^ (USA) [15112313] Cross-sectional | 160 | Suspected shoulder pathology | 5 MRI facilities located within orthopedic practices | Artoscan [Esaote Biomedica, Genoa, Italy and GE Medical Systems/Lunar Corporation, Madison, WI] (0.2T) | Operative findings, ascertained from operative reports. The operative findings were considered as the reference test. | Shoulder | Diagnostic accuracy for rotator cuff disease or glenoid labrum lesions (two radiologists reviewed MRI images independently; MRI imaging reports were available to the surgeons at the time of surgery)
Pfahler, 1998^15^ (Germany) [9932184] Cross-sectional^f^ | 34 | Lateral epicondylitis of the elbow resistant to treatment of at least 3 months | Single academic center | Dedicated system specially constructed for examination of the peripheral joints (0.2T) | Results from plain radiographs are presented (with no statistical comparison). Histopathological analysis of the extensor tendon was performed for 6 patients that underwent surgery. | Elbow | Diagnostic accuracy (number of positive MRI findings among symptomatic patients), comparison of findings in surgery (pathological examination of specimens obtained from 6 patients that underwent surgery)
Riel, 1999^14^ (Germany) [10024961] Cross-sectional | 244 | Patients with internal knee joint lesions | Single academic center | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Arthroscopy performed within “about” 48 hours of MRI. | Knee | Diagnostic accuracy (MRI scans were read by assessors blind to the orthopedic diagnosis and graded according to Reicher’s classification. Arthroscopy was performed by a single surgeon)
Steinborn, 1999^13^ (Germany) [10460377] Case-control | 23 | Lateral epicondylitis of the elbow | Single academic center | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Comparison of radiologist-assigned grades obtained with different imaging sequences. For 11 of the 23 patients findings in the contralateral, unaffected elbow were compared with the affected one. Five patients underwent surgery within 6 weeks of the MRI examination and biopsy of the common extensor tendon was obtained. Intraoperative and histopathological findings were compared with MRI findings. Grading of MRI images using the same system as for patients w | Elbow | Grading of imaging findings in all patient groups using different imaging sequences. (two radiologists employed a common grading system)
Steinborn, 1999^13^ (Germany) [10460377] Case-control | 7 | Healthy volunteers | Single academic center | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | | Elbow | Grading of imaging findings in all patient groups using different imaging sequences. (two radiologists employed a common grading system)
Verhoek, 1998^59^ (Switzerland) [9626891] Cross-sectional | 41^g^ | Consecutive patients referred for foot or ankle MRI | NR | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | High-field MRI-Impact [Siemens, Erlangen, Germany] (1.0T) | Foot; ankle | Image quality (qualitative and quantitative comparison of images obtained with the two devices in a blind manner) Patient preferences were assessed by questionnaire administered after both scans were completed.
Masciocchi, 1997^60^ (Italy) [9481587] | 58 | “Painful syndrome” at the peritalar region | NR | “dedicated” system consisting of 0.2T and 0.5T equipment | Arthroscopy was performed in 22 cases and 36 patients were assigned to clinical follow-up.^h^ | Ankle | Assignment of patients to diagnostic groups based on lesion site (visual assessment for E-MRI, surgical/arthroscopy findings or clinical follow-up findings).
Franklin, 1997^61^ (USA) [9167821] Cross-sectional | 35 | Acute or chronic knee pain that requiring arthroscopic evaluation | Single clinical practice | Artoscan [Lunar Corp., Madison, WI] (0.2T) | Arthroscopic evaluation | Knee | Diagnostic accuracy (EX MRI readings were considered as the index test and arthroscopic findings as the reference standard, assessors of each test were blind to the results of the other)
Kersting-Sommerhoff, 1996^35^ (Germany) [8798043] Cross-sectional | 230 | Acute and chronic lesions of the knee | Radiology department in a single academic center | Artoscan [Esaote Biomedica, Genoa, Italy] (0.18T) | Arthroscopic evaluation (for all patients) and high-field strength MRI (for 20^i^ patients)-ACS II [Philips, Eindhoven] (1.5T) | Knee | Diagnostic accuracy of EX-MRI compared to arthroscopic findings; image quality compared to high-field strength MRI; inter-rater agreement (3 raters) assessed in 20 patients (diagnostic accuracy was assessed at the lesion level and image quality was graded as “excellent”, “good”, “satisfactory”, or “non-diagnostic”)
Fracture or other acute injury
Bretlau, 1999^62^ (Denmark) [10622486] Prospective longitudinal study | 52 of whom 47 were successfully imaged | Trauma patients with suspected scaphoid fracture. | NR | Artoscan [Esaote Biomedica, Genoa, Italy] (0.1T) | Plain radiographs (normal at the initial examination) were compared to E-MRI images (obtained within an average of 4 days after trauma). E-MRI scans were also obtained at an average of 11 days post trauma. Late plain radiographs (average 11 weeks after trauma) were used as the reference test. Late E-MRI scans were also performed. | Wrist | Presence of a scaphoid fracture (blind assessment by two radiologists in random order)
Raby, 2001^63^ (UK) [11286584] Cross-sectional^j^ | 53 | Patients at least 10 days post-injury with suspected scaphoid fracture | Review and fracture clinics of a single center | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Management decisions based on radiological findings and clinical examination. | Wrist | Impact on treatment decisions (clinicians were asked to determine their treatment plan on the basis of clinical and radiological findings, before MRI had been obtain and they were also asked to revise the treatment plan after the MRI results were available) A rudimentary cost analysis is presented in the discussion section of the manuscript.
Raby, 2001^63^ (UK) [11286584] Cross-sectional^j^ | 56 | Patients with acute wrist injury and suspected scaphoid fracture attending the Accident and Emergency Department for the first time, usually at the day of injury | Accident and Emergency Department of a single center | Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Management decisions based on radiological findings and clinical examination. | Wrist
Nikken, 2005^64^ (Netherlands) [16118171] RCT | 500 [1:1 randomization] | Acute injury of the wrist, knee or ankle | Single university hospital | Plain radiographs followed by E-MRI with Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Plain radiographs only | Wrist; knee; ankle | Effectiveness (quality of life, time-to-completion of the diagnostic workup, number of additional diagnostic procedures during followup, number of days absent from work, number of days to convalescence) and costs (measures of medical and nonmedical costs associated with the initial injury during the 6-month followup period, societal perspective).
Niken, 2005^65^ (Netherlands) [15618379] Retrospective analysis of RCT data to develop predictive^k^ models | 90 of whom 87 were randomized | Acute injury of the wrist | Single university hospital | Plain radiographs followed by E-MRI with Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Plain radiographs only | Wrist | Additional treatment after initial presentation (the outcome was assessed at followup visits and clinical or imaging findings were assessed as potential predictors in multivariable models).
Oei, 2005^66^ (Netherlands) [15618380] l | 189 | Acute injury of the knee | Single university hospital | Plain radiographs followed by E-MRI with Artoscan [Esaote Biomedica, Genoa, Italy] (0.2T) | Plain radiographs only | Knee | Additional treatment after initial presentation (the outcome was assessed at followup visits and clinical or imaging findings were assessed as potential predictors in multivariable models).
Kühne, 1998^67^ (Germany) [9474630] Cross-sectional^m^ | 28 | ACL reconstruction within 3 to 5 years | Academic hospitals | Artoscan [Esaote Biomedica, Italy] (0.2T) | Correlation of imaging (MRI) and clinical (knee stability) outcomes in patients treated with two different methods of ACL reconstruction | Knee | MRI and clinical scores for knee stability (Clinical measurements using the KT-1000 arthrometer; MRI scores based on visual assessment)

ACL=anterior cruciate ligament; CT=computerized tomography; EULAR=European League Against Rheumatism; MCP=metacarpophalangeal; MOST=Multicenter Osteoarthritis Study; MRI=magnetic resonance imaging; NR=not reported; OMERACT=Outcomes of Rheumatoid Arthritis Clinical Trials; P=interphalangeal, RA=rheumatoid arthritis; RAMRIS=Rheumatoid Arthritis MRI Scoring System; RCT=randomized controlled trial.

a The study recruited 20 patients of whom 5 were excluded because of “lack of display of the ACL on parts of the image series.” Of the 15 patients analyzed, 5 were imaged with a 1.T superconducting magnet and were not included in our analyses.

b Three hundred sixty patients were screened, 302 met the inclusion criteria and the first 300 were selected for the study.

c The authors used the protocol described in Roemer, 2005.

d It is not clear whether participant recruitment was prospective or retrospective.

e Twenty-five patients were enrolled but one patient did not complete the required followup period of 1 year (withdrew due to “personal reasons”).

f Baseline data were reported on all 34 patients. During followup, six patients underwent surgery because they remained refractory to conservative treatment.

g A total of 47 patients were asked to participate, and 6 refused or were unable.

h Thirty-one patients had undergone conventional radiography and 18 had undergone CT. No results from these investigations were reported.

i The study reported that comparative EX-MRI and high-field strength MRI examinations were done in “more than 50 patients,” 20 of whom were recruited “prospectively.” Data were reported only regarding the latter group.

j The main analyses in the study were based on changes in the management plan (comparison of the treatment plan before and after imaging results were reported to the clinician) engendered by MRI. There was an attempt to followup patients but the response rate was too low and the effort was abandoned.

k This is a secondary analysis of data from the Nikken, 2005 RCT, listed on the above row.

l This is a secondary analysis of data from the Nikken, 2005 RCT, listed two rows above.

m A single MRI examination was performed at a mean followup time of 46 months following surgery. Only data at the followup visit are analyzed in the manuscript.

## Summary of Study Characteristics

Overall, we identified 36 relevant studies that examined dedicated extremity MRI devices.2–37 Reviewed studies were conducted among a variety of patient populations; the most common conditions evaluated were rheumatoid arthritis (15 studies), extremity injuries (5 studies) and osteoarthritis (4 studies). Twelve studies had a case-control design, 16 were cross-sectional, and 7 were longitudinal studies. Three studies reported on primary (efficacy and cost) or secondary (predictive modeling) analyses based on a randomized controlled trial comparing a testing versus no testing strategy in patients with acute extremity injuries. Twenty six studies directly (in the same patients) compared two or more diagnostic modalities. Sample sizes were generally small, with an average of 80 cases (median = 38; interquartile range [IQR]: 23, 97) and 14 controls (median = 7; IQR: 5, 12; only for case-control studies). The majority of studies used low-field strength scanners manufactured by Esaote Biomedica (Genoa, Italy) or MagneVu (Carlsbad, CA).

In general, the literature on dedicated extremity MRI appeared to be more developed as compared to stress-loading MRI studies, as our search returned multiple comparative studies assessing clinical outcomes and studies with more rigorous designs, including a randomized trial of imaging with MRI in addition to plain radiograph versus radiographs alone (discussed below).

## Randomized Controlled Trial of Dedicated Extremity MRI

We identified one randomized trial comparing plain radiographs followed by dedicated extremity MRI imaging versus plain radiographs alone for the diagnosis of acute extremity injuries. The study was conducted in a single academic center and enrolled 500 patients with acute injuries of the wrist, knee, or ankle, randomized 1:1 to the two diagnostic interventions. The dedicated extremity scanner used was the Artoscan (Esaote Biomedica, Genoa, Italy) MRI device, which has a magnetic field strength of 0.2T. The primary analysis of the trial reported on clinical effectiveness (assessed based on qualityof life measurements, time -to-completion of the diagnostic workup, number of additional diagnostic procedures during follow-up, number of days absent from work, and number of days to convalescence) and costs (measures of medical and nonmedical expenses associated with the initial injury during the 6-month followup period, as well as societal costs). Secondary analyses based on data obtained from the same clinical trial population were published separately and reported on the development of models for predicting the need for additional treatment after initial presentation.

## Current Availability of Dedicated Extremity MRI

In late 2009, GE entered into an agreement to purchase certain assets of ONI Medical Systems, Inc., a privately held company headquartered in Wilmington, Massachusetts, USA.38 According to the KI affiliated with GE Healthcare, GE Healthcare is marketing two versions of a dedicated extremity MRI scanner (MSK Extreme 1.0T and the MSK Extreme 1.5T), and approximately 150 such devices are installed, with field strengths of 1.0 to 1.5 T. Based on a press release concerning the ONI MSK Extreme (GE Healthcare), as of October 21, 2009, the MSK Extreme had an installed base of 175 scanners worldwide.39 The availability of lower field strength dedicated extremity MRI scanners is estimated to be larger given that they have been on the market for a longer time. Generally, because of their relatively low installation requirements, dedicated extremity MRI scanners are marketed to private orthopedic or rheumatology physician practices. Multiple manufacturing company Web sites, in addition to KI input, have suggested that these devices are also commonly used as “capacity enhancers,” that is, they are installed in facilities that already have several whole-body conventional scanners to increase the total volume of MRI scans these facilities can offer. To the best of our knowledge, the MagneVu 1000 device, a dedicated extremity MRI device, is not available commercially (the manufacturer appears to have filed for bankruptcy);^a^ however, there exists an installed base of somewhat less than 100 devices.

a Available at: http://www.auntminnie.com/index.asp?sec=ser&sub=def&pag=dis&ItemID=77843, last accessed October 10, 2010. The company’s Web site is no longer available (www.magnevu.com, last attempt to access: October 10, 2010).

## Possible Future Research

Dedicated extremity MRI scanners are typically not used in stress-loading applications; however, KIs suggested that this could be a promising area of future research. We identified extremely limited use of dedicated extremity MRI under stress loading. However, the availability of high-field strength systems makes this an interesting area for future research. In addition, the availability of low- and high-field strength devices would allow for opportunities to directly compare the diagnostic accuracy of low- and high-field strength systems.

## Summary and Implications

Due to their unique design (“semi-open” configuration) and the fact that they are not often utilized to take images under stress-loading conditions (at least in the currently available literature), we decided to assess dedicated extremity MRI scanners separately from other emerging technologies included in this report. We identified a large number of published studies, often comparative and assessing clinical outcomes, including a randomized controlled trial of testing versus no-testing. It appears that these devices are commonly used in rheumatology (mostly for rheumatoid and other inflammatory arthritides) as well as the initial evaluation of acute extremity (wrist, knee, and ankle) trauma. Given the relatively recent availability of higher field strength dedicated extremity MRI scanners, further increases in the utilization of such devices are expected. All considerations for future studies described in the Next Steps section of the main report apply equally to dedicated extremity MRI devices.

## Future Steps for Assessing Dedicated Extremity MRI Scanners

The literature on dedicated extremity MRI scanners appears to be fairly extensive and more mature compared to the other technologies discussed herein. Given the recent availability of high-field strength dedicated extremity scanners, we believe that a systematic review or technology assessment of their use for the diagnosis and monitoring of patients with rheumatoid arthritis and other inflammatory arthritides may be warranted.

## References to Studies of Dedicated Extremity MRI

1 Mastrokalos DS, Papagelopoulos PJ, Mavrogenis AF, et al. Changes of meniscal interhorn distances: an in vivo magnetic resonance imaging study. Knee. 2005;12:441-6. [pmid: 15967666].
2 Segal NA, Anderson DD, Iyer KS, et al. Baseline articular contact stress levels predict incident symptomatic knee osteoarthritis development in the MOST cohort. Journal of Orthopaedic Research. 2009;27:1562-8. [pmid: 19533741].
3 Schiff MH, Hobbs KF, Gensler T, et al. A retrospective analysis of low-field strength magnetic resonance imaging and the management of patients with rheumatoid arthritis. Current Medical Research & Opinion. 2007;23:961-8. [pmid: 17519063].
4 Lindegaard HM, Vallo J, Horslev-Petersen K, et al. Low-cost, low-field dedicated extremity magnetic resonance imaging in early rheumatoid arthritis: a 1-year follow-up study. Annals of the Rheumatic Diseases. 2006;65:1208-12. [pmid: 16540550].
5 Eshed I, Althoff CE, Schink T, et al. Low-field MRI for assessing synovitis in patients with rheumatoid arthritis. Impact of Gd-DTPA dose on synovitis scoring. Scandinavian Journal of Rheumatology. 2006;35:277-82. [pmid: 16882591].
6 Nikken JJ, Oei EH, Ginai AZ, et al. Acute peripheral joint injury: cost and effectiveness of low-field-strength MR imaging--results of randomized controlled trial. Radiology. 2005;236:958-67. [pmid: 16118171].
7 Roemer FW, Guermazi A, Lynch JA, et al. Short tau inversion recovery and proton density-weighted fat suppressed sequences for the evaluation of osteoarthritis of the knee with a 1.0 T dedicated extremity MRI: development of a time-efficient sequence protocol. European Radiology. 2005;15:978-87. [pmid: 15633060].
8 Oei EH, Nikken JJ, Ginai AZ, et al. Acute knee trauma: value of a short dedicated extremity MR imaging examination for prediction of subsequent treatment. Radiology. 2005;234:125-33. [pmid: 15618380].
9 Nikken JJ, Oei EH, Ginai AZ, et al. Acute wrist trauma: value of a short dedicated extremity MR imaging examination in prediction of need for treatment. Radiology. 2005;234:116-24. [pmid: 15618379].
10 Taouli B, Zaim S, Peterfy CG, et al. Rheumatoid arthritis of the hand and wrist: comparison of three imaging techniques. AJR. 2004;American:937-43. [pmid: 15039167].
11 Lindegaard H, Vallo J, Horslev-Petersen K, et al. Low field dedicated magnetic resonance imaging in untreated rheumatoid arthritis of recent onset. Annals of the Rheumatic Diseases. 2001;60:770-6. [pmid: 11454641].
12 Raby N. Magnetic resonance imaging of suspected scaphoid fractures using a low field dedicated extremity MR system. Clinical Radiology. 2001;56:316-20. [pmid: 11286584].
13 Steinborn M, Heuck A, Jessel C, et al. Magnetic resonance imaging of lateral epicondylitis of the elbow with a 0.2-T dedicated system. European Radiology. 1999;9:1376-80. [pmid: 10460377].
14 Riel KA, Reinisch M, Kersting-Sommerhoff B, et al. 0.2-Tesla magnetic resonance imaging of internal lesions of the knee joint: a prospective arthroscopically controlled clinical study. Knee Surgery, Sports Traumatology, Arthroscopy. 1999;7:37-41.
15 Pfahler M, Jessel C, Steinborn M, et al. Magnetic resonance imaging in lateral epicondylitis of the elbow. Archives of Orthopaedic & Trauma Surgery. 1998;118:121-5. [pmid: 9932184].
16 Masciocchi C, Maffey MV, Mastri F. Overload syndromes of the peritalar region. European Journal of Radiology. 1997;26:46-53. [pmid: 9481587].
17 Duer-Jensen A, Ejbjerg B, brecht-Beste E, et al. Does low-field dedicated extremity MRI (E-MRI) reliably detect bone erosions in rheumatoid arthritis? A comparison of two different E-MRI units and conventional radiography with high-resolution CT scanning. Annals of the Rheumatic Diseases. 2009;68:1296-1302. [pmid: 18718987].
18 Duer-Jensen A, Vestergaard A, Dohn UM, et al. Detection of rheumatoid arthritis bone erosions by two different dedicated extremity MRI units and conventional radiography. Annals of the Rheumatic Diseases. 2008;67:998-1003. [pmid: 17984195].
19 Freeston JE, Conaghan PG, Dass S, et al. Does extremity-MRI improve erosion detection in severely damaged joints? A study of long-standing rheumatoid arthritis using three imaging modalities. Annals of the Rheumatic Diseases. 2007;66:1538-40. [pmid: 17666445].
20 Gaylis NB, Needell SD, Rudensky D. Comparison of in-office magnetic resonance imaging versus conventional radiography in detecting changes in erosions after one year of infliximab therapy in patients with rheumatoid arthritis. Modern Rheumatology. 2007;17:273-8. [pmid: 17694258].
21 Yoshioka H, Ito S, Handa S, et al. Low-field compact magnetic resonance imaging system for the hand and wrist in rheumatoid arthritis. J Magn Reson Imaging. 2006;23:370-6. [pmid: 16456819].
22 Xie X, Webber CE, Adachi JD, et al. Quantitative, small bore, 1 Tesla, magnetic resonance imaging of the hands of patients with rheumatoid arthritis. Clinical & Experimental Rheumatology. 2008;26:860-5. [pmid: 19032820].
23 Ejbjerg BJ, Narvestad E, Jacobsen S, et al. Optimised, low cost, low field dedicated extremity MRI is highly specific and sensitive for synovitis and bone erosions in rheumatoid arthritis wrist and finger joints: comparison with conventional high field MRI and radiography. Annals of the Rheumatic Diseases. 2005;64:1280-7. [pmid: 15650012].
24 Cimmino MA, Parodi M, Innocenti S, et al. Dynamic magnetic resonance of the wrist in psoriatic arthritis reveals imaging patterns similar to those of rheumatoid arthritis. Arthritis Research & Therapy. 2005;7:R725-31. [pmid: 15987474].
25 Zlatkin MB, Hoffman C, Shellock FG. Assessment of the rotator cuff and glenoid labrum using an extremity MR system: MR results compared to surgical findings from a multi-center study. J Magn Reson Imaging. 2004;19:623-31. [pmid: 15112313].
26 Pessis E, Drape JL, Ravaud P, et al. Assessment of progression in knee osteoarthritis: results of a 1 year study comparing arthroscopy and MRI. Osteoarthritis & Cartilage. 2003;11:361-9. [pmid: 12744942].
27 Cimmino MA, Innocenti S, Livrone F, et al. Dynamic gadolinium-enhanced magnetic resonance imaging of the wrist in patients with rheumatoid arthritis can discriminate active from inactive disease. Arthritis & Rheumatism. 2003;48:1207-13. [pmid: 12746893].
28 Savnik A, Malmskov H, Thomsen HS, et al. MRI of the arthritic small joints: comparison of extremity MRI (0.2 T) vs high-field MRI (1.5 T). European Radiology. 2001;11:1030-8. [pmid: 11419149].
29 Jagodzinski M, Richter GM, Passler HH. Biomechanical analysis of knee hyperextension and of the impingement of the anterior cruciate ligament: a cinematographic MRI study with impact on tibial tunnel positioning in anterior cruciate ligament reconstruction. Knee Surgery, Sports Traumatology, Arthroscopy. 2000;8:11-19.
30 Tajiri Y, Nakamura K, Matsushita T, et al. A positioning device to allow rotation for cine-MRI of the distal radioulnar joint. Clinical Radiology. 1999;54:402-5. [pmid: 10406343].
31 Bretlau T, Christensen OM, Edstrom P, et al. Diagnosis of scaphoid fracture and dedicated extremity MRI. Acta Orthopaedica Scandinavica. 1999;70:504-8. [pmid: 10622486].
32 Verhoek G, Zanetti M, Duewell S, et al. MRI of the foot and ankle: diagnostic performance and patient acceptance of a dedicated low field MR scanner. J Magn Reson Imaging. 1998;8:711-16. [pmid: 9626891].
33 Crues JV, Shellock FG, Dardashti S, et al. Identification of wrist and metacarpophalangeal joint erosions using a portable magnetic resonance imaging system compared to conventional radiographs. The Journal of Rheumatology. 2004;31:676-85. [pmid: 15088291].
34 Franklin PD, Lemon RA, Barden HS. Accuracy of imaging the menisci on an in-office, dedicated, magnetic resonance imaging extremity system. American Journal of Sports Medicine. 1997;25:382-8. [pmid: 9167821].
35 Kersting-Sommerhoff B, Hof N, Lenz M, et al. MRI of peripheral joints with a low-field dedicated system: a reliable and cost-effective alternative to high-field units?. European Radiology. 1996;6:561-5. [pmid: 8798043].
36 Drape JL, Pessis E, Auleley GR, et al. Quantitative MR imaging evaluation of chondropathy in osteoarthritic knees. Radiology. 1998;208:49-55. [pmid: 9646792].
37 Kuhne JH, Durr HR, Steinborn M, et al. Magnetic resonance imaging and knee stability following ACL reconstruction. Orthopedics. 1998;21:39-43. [pmid: 9474630].
38 GE Healthcare News. GE Healthcare 10-21-2009. 10. 10. 2010. Ref Type: Electronic Citation.
39 GE Expands into Extremity-Specific MRI Systems, Grows Product Line. GE Healthcare News 2009. 10. 11. 2010. Ref Type: Electronic Citation.
40 Xie X, Webber CE, Adachi JD, et al. Quantitative, small bore, 1 Tesla, magnetic resonance imaging of the hands of patients with rheumatoid arthritis. Clinical & Experimental Rheumatology. 2008;26:860-5. [pmid: 19032820].
41 Yoshioka H, Ito S, Handa S, et al. Low-field compact magnetic resonance imaging system for the hand and wrist in rheumatoid arthritis. J Magn Reson Imaging. 2006;23:370-6. [pmid: 16456819].
42 Duer-Jensen A, Vestergaard A, Dohn UM, et al. Detection of rheumatoid arthritis bone erosions by two different dedicated extremity MRI units and conventional radiography. Annals of the Rheumatic Diseases. 2008;67:998-1003. [pmid: 17984195].
43 Cimmino MA, Innocenti S, Livrone F, et al. Dynamic gadolinium-enhanced magnetic resonance imaging of the wrist in patients with rheumatoid arthritis can discriminate active from inactive disease. Arthritis & Rheumatism. 2003;48:1207-13. [pmid: 12746893].
44 Duer-Jensen A, Ejbjerg B, brecht-Beste E, et al. Does low-field dedicated extremity MRI (E-MRI) reliably detect bone erosions in rheumatoid arthritis? A comparison of two different E-MRI units and conventional radiography with high-resolution CT scanning. Annals of the Rheumatic Diseases. 2009;68:1296-1302. [pmid: 18718987].
45 Ejbjerg BJ, Narvestad E, Jacobsen S, et al. Optimised, low cost, low field dedicated extremity MRI is highly specific and sensitive for synovitis and bone erosions in rheumatoid arthritis wrist and finger joints: comparison with conventional high field MRI and radiography. Annals of the Rheumatic Diseases. 2005;64:1280-7. [pmid: 15650012].
46 Freeston JE, Conaghan PG, Dass S, et al. Does extremity-MRI improve erosion detection in severely damaged joints? A study of long-standing rheumatoid arthritis using three imaging modalities. Annals of the Rheumatic Diseases. 2007;66:1538-40. [pmid: 17666445].
47 Tajiri Y, Nakamura K, Matsushita T, et al. A positioning device to allow rotation for cine-MRI of the distal radioulnar joint. Clinical Radiology. 1999;54:402-5. [pmid: 10406343].
48 Roemer FW, Guermazi A, Lynch JA, et al. Short tau inversion recovery and proton density-weighted fat suppressed sequences for the evaluation of osteoarthritis of the knee with a 1.0 T dedicated extremity MRI: development of a time-efficient sequence protocol. European Radiology. 2005;15:978-87. [pmid: 15633060].
49 Schiff MH, Hobbs KF, Gensler T, et al. A retrospective analysis of low-field strength magnetic resonance imaging and the management of patients with rheumatoid arthritis. Current Medical Research & Opinion. 2007;23:961-8. [pmid: 17519063].
50 Segal NA, Anderson DD, Iyer KS, et al. Baseline articular contact stress levels predict incident symptomatic knee osteoarthritis development in the MOST cohort. Journal of Orthopaedic Research. 2009;27:1562-8. [pmid: 19533741].
51 Taouli B, Zaim S, Peterfy CG, et al. Rheumatoid arthritis of the hand and wrist: comparison of three imaging techniques. AJR. 2004;American:937-43. [pmid: 15039167].
52 Lindegaard H, Vallo J, Horslev-Petersen K, et al. Low field dedicated magnetic resonance imaging in untreated rheumatoid arthritis of recent onset. Annals of the Rheumatic Diseases. 2001;60:770-6. [pmid: 11454641].
53 Lindegaard HM, Vallo J, Horslev-Petersen K, et al. Low-cost, low-field dedicated extremity magnetic resonance imaging in early rheumatoid arthritis: a 1-year follow-up study. Annals of the Rheumatic Diseases. 2006;65:1208-12. [pmid: 16540550].
54 Eshed I, Althoff CE, Schink T, et al. Low-field MRI for assessing synovitis in patients with rheumatoid arthritis. Impact of Gd-DTPA dose on synovitis scoring. Scandinavian Journal of Rheumatology. 2006;35:277-82. [pmid: 16882591].
55 Crues JV, Shellock FG, Dardashti S, et al. Identification of wrist and metacarpophalangeal joint erosions using a portable magnetic resonance imaging system compared to conventional radiographs. The Journal of Rheumatology. 2004;31:676-85. [pmid: 15088291].
56 Drape JL, Pessis E, Auleley GR, et al. Quantitative MR imaging evaluation of chondropathy in osteoarthritic knees. Radiology. 1998;208:49-55. [pmid: 9646792].
57 Pessis E, Drape JL, Ravaud P, et al. Assessment of progression in knee osteoarthritis: results of a 1 year study comparing arthroscopy and MRI. Osteoarthritis & Cartilage. 2003;11:361-9. [pmid: 12744942].
58 Zlatkin MB, Hoffman C, Shellock FG. Assessment of the rotator cuff and glenoid labrum using an extremity MR system: MR results compared to surgical findings from a multi-center study. J Magn Reson Imaging. 2004;19:623-31. [pmid: 15112313].
59 Verhoek G, Zanetti M, Duewell S, et al. MRI of the foot and ankle: diagnostic performance and patient acceptance of a dedicated low field MR scanner. J Magn Reson Imaging. 1998;8:711-16. [pmid: 9626891].
60 Masciocchi C, Maffey MV, Mastri F. Overload syndromes of the peritalar region. European Journal of Radiology. 1997;26:46-53. [pmid: 9481587].
61 Franklin PD, Lemon RA, Barden HS. Accuracy of imaging the menisci on an in-office, dedicated, magnetic resonance imaging extremity system. American Journal of Sports Medicine. 1997;25:382-8. [pmid: 9167821].
62 Bretlau T, Christensen OM, Edstrom P, et al. Diagnosis of scaphoid fracture and dedicated extremity MRI. Acta Orthopaedica Scandinavica. 1999;70:504-8. [pmid: 10622486].
63 Raby N. Magnetic resonance imaging of suspected scaphoid fractures using a low field dedicated extremity MR system. Clinical Radiology. 2001;56:316-20. [pmid: 11286584].
64 Nikken JJ, Oei EH, Ginai AZ, et al. Acute peripheral joint injury: cost and effectiveness of low-field-strength MR imaging--results of randomized controlled trial. Radiology. 2005;236:958-67. [pmid: 16118171].
65 Nikken JJ, Oei EH, Ginai AZ, et al. Acute wrist trauma: value of a short dedicated extremity MR imaging examination in prediction of need for treatment. Radiology. 2005;234:116-24. [pmid: 15618379].
66 Oei EH, Nikken JJ, Ginai AZ, et al. Acute knee trauma: value of a short dedicated extremity MR imaging examination for prediction of subsequent treatment. Radiology. 2005;234:125-33. [pmid: 15618380].
67 Kuhne JH, Durr HR, Steinborn M, Jansson V, et al. Magnetic resonance imaging and knee stability following ACL reconstruction. Orthopedics. 1998;21:39-43. [pmid: 9474630].