# Shared Authorship Patterns in Studies of Weight-Bearing or Stress-Loading MRI

The figure below demonstrates that a total of 55 publications (reporting on 56 studies) were conducted by 32 teams of investigators. One team that has published six manuscripts, corresponding to approximately 11 percent of all studies we considered eligible, includes as coauthors Drs. Danielson and Willen, inventors of the DynaWell axial loading device.^a^ We caution that our graph does not necessarily imply overlap of patient populations, and it should rather be regarded as a method to identify the most active research groups in the field.

a DynaWell Diagnostics. DynaWell(R). http://www.dynawell.biz.

Appendix D Figure 1 is a graph demonstrating the extent of shared authorship across the studies we considered. Shared authorship patterns in studies of weight-bearing or stress-loading MRI are depicted as an undirected graph. Each publication is represented by an ellipse, with studies sharing at least one author depicted as a group of ellipses linked with lines. Refer to the Methods section for a description of how the graph was generated. Overall, there appears to be a substantial amount of shared authorship. Specifically, there are total of 55 publications were conducted by 32 teams of investigators. One team that has published 6 manuscripts, corresponding to approximately 11 percent of all studies we considered eligible includes as co-authors Drs. Danielson and Willen, inventors of the DynaWell axial loading device. We caution that our graph does not necessarily imply overlap of patient populations, and should rather be regarded as a method to identify the most active research groups in the field.

Overlap between author lists in included studies. Each publication is represented by an ellipse. Studies sharing at least one author are depicted as a group of ellipses linked amongst themselves with lines. Refer to the Methods Section for a description of how the graph was generated.