# Search Strategy

We present here our search strategy (appropriate for Ovid MEDLINE) for studies of MRI under stress loading. We used a composite search strategy combining methodological terms for studies of diagnostic tests, MRI imaging and the diseases of interest (musculoskeletal disorders).

1 exp Magnetic Resonance Imaging/
2 (“Magnetic Resonance Imaging” or “MRI”).tw.
3 1 or 2
4 (“dynamic” or “vertical” or “upright” or “stand*” or “seat*” or “open” or “position*” or “weight bearing”).tw. or ((“axial$” and “load$”) or (“extremity specific” or “dedicated”)).tw.
5 3 and 4
6 limit 5 to yr=“1975 -Current”
7 limit 6 to (english language and humans)
8 exp “sensitivity and specificity”/
9 exp Predictive Value of Tests/
10 exp ROC CURVE/
11 exp Mass Screening/
12 exp diagnosis/
13 exp REPRODUCIBILITY OF RESULTS/
14 exp false negative reactions/or false positive reactions/
15 predictive value.tw.
16 (sensitivity or specificity).tw.
17 accuracy.tw.
18 screen$.tw.
19 diagno$.tw.
20 roc.tw.
21 reproducib$.tw.
22 (false positive or false negative).tw.
23 likelihood ratio.tw.
24 di.fs.
25 or/8–24
26 (cf or bl or ra or ri or us or en).fs.
27 25 or 26
28 7 and 27
29 limit 28 to (addresses or bibliography or biography or case reports or comment or dictionary or directory or duplicate publication or editorial or guideline or in vitro or interview or lectures or legal cases or letter or news or newspaper article or “review”)
30 28 not 29
31 exp Cervical Vertebrae/
32 (“cervical myelopathy” or “cervical spine” or “cervical spondylotic myelopathy” or “Dural sac” or “Facet” or “Herniation” or “instability” or “intervertebral disc”).tw.
33 exp Intervertebral Disk Displacement/
34 exp Intervertebral Disk/
35 (“kyphosis” or “lordosis” or “low* back”).tw.
36 exp Low Back Pain/
37 (“lumbar” or “lumbar stenosis”).tw.
38 exp Lumbar Vertebrae/
39 exp Neck Pain/
40 exp Neck/
41 (“neck” or “radicul*”).tw.
42 exp Radiculopathy/
43 exp Sciatica/
44 sciatica.tw.
45 (scoliosis or spinal).tw.
46 exp Spinal Curvatures/
47 spinal osteophytosis/ or spinal stenosis/ or spondylolisthesis/ or thoracic vertebrae/ or whiplash injuries/
48 (“spinal stenosis” or “spine” or “spondylolisthesis” or “spondylosis”).tw.
49 exp Joints/
50 (“foot” or “feet” or “knee*” or “hip$” or “TMJ” or “temporomandibular” or “shoulder*” or “elbow” or “wrist*” or “hand$”).tw.
51 or/31–50
54 30 and 51