# Acknowledgments

We thank the key informants for their contributions. We thank Ramon C. Iovin, Ph.D., and Srila Sen, M.A., the report’s medical editors.