# Glossary

Biologically Effective Dose: The dose deposited corrected for variation in biological response.
Collimator: Defines the dimensions and direction of a beam of x-ray radiation, usually by eliminating the peripheral, more divergent part of the x-ray beam.
Fiducial: Markers that help to precisely identify the targeted tumor location. They may be located on a head frame, or surgically implanted for tumor locations throughout the body.
Fractionation: Dividing a prescribed treatment dose into smaller amounts.
Gray: A measure of the absorbed radiation dose and equal to the absorption of one joule of energy by one kilogram of matter.
Multi-leaf Collimator: A device with individual tungsten leaves that are programmed to moved independently in order to shape the prescribed beam profile to the targeted tumor.