# Abbreviations

2D-CRT: Conventional radiation therapy
3D-CRT: Three-dimensional conformal radiation therapy
AAA: Anisotropic analytical algorithm
AAPM: American Association of Physicists in Medicine
ABC: Active breathing control
ACR: The American College of Radiology
AHA: The American Hospital Association
AHRQ: The Agency for Healthcare Research and Quality
ASTRO: American Society for Radiation Oncology
AVM: Arteriovenous malformation
BED: Biologically effective dose
Bq: Becquerel
CDRH: Center for Devices and Radiological Health
cGY/min: Centigray per minute
cm: Centimeter
CNS: Central nervous system
COPD: Chronic obstructive pulmonary disease
CRR: Clinical response rate
CT: Computed tomography
CT/MR: Computer tomography/magnetic resonance
CTC: Common toxicity criteria
DF: Distant failure
DFS: Disease-free survival
DMMLC: Dynamic Micro Multileaf Collimator
DOF: Degrees of freedom
DPFS: Disease progression-free survival
DRR: Digitally reconstructed radiographs
DSS: Disease-specific survival
DVH: Dose volume histogram
EBRT: External beam radiation therapy
ECOG: Eastern Cooperative Oncology Group
FDA: United States Food and Drug Administration
Gy: Gray
HCC: Hepatocellular carcinoma
HD: High definition
hFSRT: Hypofractionated stereotactic radiotherapy
HRQoL: Health-related quality of life
HSBRT: Hypofractionated stereotactic body radiotherapy
IGRT: Image guided radiation therapy
IHC: Intrahepatic cholangiocarcinoma
IMRT: Intensity modulated radiation therapy
IMSRS: Intensity modulated stereotactic radiosurgery
KPS: Karnofsky Performance Status
KV: Kilovolt
KVp: Peak kilovoltage
LC: Local control
LCR: Local control rate
LED: Light emitting diode
LF: Local failure
Linac: Linear accelerator
LP: Local progression
LQ: Linear quadratic model
M: Male
MD: Minimum dose
MEV: Million electron volt
MLC: Multi-leaf collimator
mm: Millimeter
mMLC: micro Multi-leaf collimator
MRI: Magnetic resonance imaging
MTD: Maximum tolerated dose
MU/min: Monitor units per minute
MV: Megavolt
MVCT: Megavoltage computed tomography
NCI-CTC: National Cancer Institute-Common Toxicity Criteria
NR: Not reported
NS: Not specified
NSCLC: Non-small cell lung cancer
NTC: Normal tissue changes
OS: Overall survival
PALN: Para-aortic lymph nodes
PET: Positron emission tomography
PFS: Progression-free survival
PSA: Prostate specific antigen
QA: Quality assurance
QALY: Quality-adjusted life years
QC: Quality control
QoL: Quality of Life
RC: Regional control
RECIST: Response evaluation criteria in solid tumors
RFA: Radiofrequency ablation
RS: Radiosurgery
RT: Radiation therapy
RTOG: Radiation Therapy Oncology Group
SBF: Stereotactic body frame
SBRT: Stereotactic body radiation therapy
SRS: Stereotactic radiosurgery
SRT: Stereotactic radiotherapy
TACE: Transcatheter arterial chemoembolization
TACI: Transarterial chemoinfusion
VMAT: Volumetric modulated arc therapy
WHO: World Health Organization