# Statement of Work

The Agency for Healthcare Research and Quality requested a Technical Brief on Stereotactic Radiosurgery for Nonbrain Cancer. The following Guiding Questions were provided to the ECRI Institute Evidence-based Practice Center (EPC):

## Guiding Question 1

1a For which cancers (other than brain) has stereotactic radiosurgery been used?
1b What are the theoretical advantages and disadvantages of stereotactic radiosurgery compared to other radiation and surgical therapies that are currently used for cancer treatment?
1c What are the potential safety issues and harms of the use of stereotactic radiosurgery?

## Guiding Question 2

2a What specialized instrumentation is needed for stereotactic radiosurgery at sites other than in the brain and what is the FDA status of this instrumentation?
2b What is an estimate of the number of hospitals that currently have the capability for stereotactic radiosurgery at sites other than the brain in the United States?
2c What instrumentation technologies are in development?

## Guiding Question 3

Systematic literature scans on studies on the use and safety of these therapies in cancers other than in the brain, with a synthesis of the following variables:

3a Type of cancer/patient inclusion criteria
3b Type of radiation/instrumentation and algorithms used
3c Study design/size
3d Comparator used in comparative studies
3e Concurrent/prior treatments
3f Length of followup
3g Outcomes measured
3h Adverse events/harms/safety issues reported

The first draft of this Technical Brief included a review of stereotactic radiosurgery(SRS) and SBRT treatment for all sites within the body (including spine and head) excluding the brain. However, based on the feedback of external reviewers and more recent working definitions of SRS and SBRT, the scope of this Technical Brief has been adjusted to focus on SBRT. The definition of SRS developed by the American Association of Neurological Surgeons (AANS), the Congress of Neurological Surgeons (CNS), and the American Society for Radiation Oncology is as follows:7

Stereotactic radiosurgery is a distinct discipline that utilizes externally generated ionizing radiation in certain cases to inactivate or eradicate (a) defined target (s) in the head or spine without the need to make an incision. The target is defined by high-resolution stereotactic imaging. To assure quality of patient care the procedure involves a multidisciplinary team consisting of a neurosurgeon, radiation oncologist, and medical physicist.

Stereotactic radiosurgery is typically performed in a single session, using a rigidly attached stereotactic guiding device, other immobilization technology and/or a stereotactic image-guidance system, but can be performed in a limited number of sessions, up to a maximum of five.

Technologies that are used to perform SRS include linear accelerators, particle beam accelerators and multisource Cobalt 60 units. In order to enhance precision, various devices may incorporate robotics and real time imaging.

The American Medical Association (AMA) has common procedural terminology (CPT) codes for SRS and SBRT that are recognized by the Centers for Medicare and Medicaid Services (CMS). According to the CPT codes, SRS treatment is delivered to a cranial lesion or spinal lesion consisting of one session (CPT codes: 77371, 77372, 77432, 63620); while SBRT has two applicable codes (77373 and 77435) with treatment delivery not to exceed five fractions within the body.8

This Brief describes the current technologies available to deliver SBRT; the types and locations of tumors that have been treated with SBRT; the possible advantages and disadvantages of the technology; the extent of diffusion of the technology; and provides information about advances in the technology that are currently in development. This Technical Brief does not assess the quality of the retrieved studies, provide analysis of study outcomes, or come to any conclusions about the reported results and adverse events.