# References

1 American College of Radiology (ACR). Practice guideline for the performance of stereotactic body radiation therapy. Reston VA. American College of Radiology (ACR). 2009:8.
2 Fuss M, Thomas CR Jr. Stereotactic body radiation therapy: an ablative treatment option for primary and secondary liver tumors. Ann Surg Oncol. 02. 2004;11(2):130-8. [pmid: 14761915].
3 Smink KA, Schneider SM. Overview of stereotactic body radiotherapy and the nursing role. Clin J Oncol Nurs. 12. 2008;12(6):889-93. [pmid: 19064382].
4 Read PW. Stereotactic body radiation therapy: 2007 Update. Community Oncol. 10. 2007;4(10):616-20.
5 Miyamoto C. (Chairperson & Professor, Department of Radiation Oncology, Temple University School of Medicine). Personal Communication. 02. 2010;23:51.
6 American College of Radiology (ACR). Practice guideline for the performance of stereotactic body radiation therapy. Reston VA. American College of Radiology (ACR). 2004:8.
7 Barnett GH, Linskey ME, Adler JR, et al. Stereotactic radiosurgery–an organized neurosurgery-sanctioned definition. J Neurosurg. 01. 2007;106(1):1-5. [pmid: 17240553].
8 Stereotactic radiotherapy (SRS)/stereotactic radiation therapy (SBRT) for Medicare plans Policy #: SURGERY 0581 T3 [Internet]. Trumbull CT. Oxford Health Plans, LLC. 01. accessed 2009; Sep 3. 2009:5. Available at https://www.oxhp.com.
9 Meyer JL, Verhey L, Xia P, et al. New technologies in the radiotherapy clinic. Front Radiat Ther Oncol. 2007;40:1-17. [pmid: 17641499].
10 Chen JC, Rahimian J, Girvigian MR, et al. Contemporary methods of radiosurgery treatment with the Novalis linear accelerator system. Neurosurg Focus. 2007;23(6):E4. [pmid: 18081481].
11 GammaStar’s Gyro Knife awarded EU certification. [Internet]. New York NY. Thomson Reuters. 2008. 04. 15. accessed 2008; Nov 25. Available at http://www.reuters.com/article/pressRelease/idUS130278+15-Apr-2008+PRN20080415.
12 American Cancer Society (ACS). Cancer facts & figures 2009. Atlanta GA. American Cancer Society (ACS). 2009:72. Also available at http://www.cancer.org/downloads/STT/500809web.pdf.
13 Kavanagh BD, Kelly K, Kane M. The promise of stereotactic body radiation therapy in a new era of oncology. Front Radiat Ther Oncol. 2007;40:340-51. [pmid: 17641518].
14 Dilling TJ, Hoffe SE. Stereotactic body radiation therapy: transcending the conventional to improve outcomes. Cancer Control. 04. 2008;15(2):104-11. [pmid: 18376377].
15 Committee on Radiation Source Use and Replacement, National Research Council. Radiation source use and replacement: abbreviated version. Washington DC. National Academies Press Radiotherapy. 2008:117-33. Also available at http://www.nap.edu/catalog.php?record_id=11976.
16 Chang BK, Timmerman RD. Stereotactic body radiation therapy: a comprehensive review. Am J Clin Oncol. 12. 2007;30(6):637-44. [pmid: 18091059].
17 Microsoft Office Excel 2007, part of Microsoft Office Professional Plus 2007 [software program]. Redmond WA. Microsoft. 2006.
18 Kavanagh BD, Timmerman RD. Stereotactic radiosurgery and stereotactic body radiation therapy: an overview of technical considerations and clinical applications. Hematol Oncol Clin North Am. 02. 2006;20(1):87-95. [pmid: 16580558].
19 Ahn SH, Han MS, Yoon JH, et al. Treatment of stage I non-small cell lung cancer with CyberKnife, image-guided robotic stereotactic radiosurgery. Oncol Rep. 03. 2009;21(3):693-6. [pmid: 19212628].
20 Baumann P, Nyman J, Hoyer M, et al. Stereotactic body radiotherapy for medically inoperable patients with stage I non-small cell lung cancer—a first report of toxicity related to COPD/CVD in a non-randomized prospective phase II study. Radiother Oncol. 09. 2008;88(3):359-67. [pmid: 18768228].
21 Chang JY, Balter PA, Dong L, et al. Stereotactic body radiation therapy in centrally and superiorly located stage I or isolated recurrent non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 11. 15. 2008;72(4):967-71. [pmid: 18954709].
22 Collins BT, Vahdat S, Erickson K, et al. Radical cyberknife radiosurgery with tumor tracking: an effective treatment for inoperable small peripheral stage I non-small cell lung cancer. J Hematol Oncol. 2009;2:1. [pmid: 19149899].
23 Guckenberger M, Wulf J, Mueller G, et al. Dose-response relationship for image-guided stereotactic body radiotherapy of pulmonary tumors: relevance of 4D dose calculation. Int J Radiat Oncol Biol Phys. 05. 1. 2009;74(1):47-54. [pmid: 18977095].
24 Haasbeek CJ, Lagerwaard FJ, de Jaeger K, et al. Outcomes of stereotactic radiotherapy for a new clinical stage I lung cancer arising postpneumonectomy. Cancer. 02. 1. 2009;115(3):587-94. [pmid: 19130457].
25 Henderson M, McGarry R, Yiannoutsos C, et al. Baseline pulmonary function as a predictor for survival and decline in pulmonary function over time in patients undergoing stereotactic body radiotherapy for the treatment of stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 10. 1. 2008;72(2):404-9. [pmid: 18394819].
26 Kawase T, Takeda A, Kunieda E, et al. Extrapulmonary soft-tissue fibrosis resulting from hypofractionated stereotactic body radiotherapy for pulmonary nodular lesions. Int J Radiat Oncol Biol Phys. 06. 1. 2009;74(2):349-54. [pmid: 19427551].
27 Kopek N, Paludan M, Petersen J, et al. Co-morbidity index predicts for mortality after stereotactic body radiotherapy for medically inoperable early-stage non-small cell lung cancer. Radiother Oncol. 12. 2009;93(1):122-4. E-pub 2009 Jun 22. [pmid: 19552979].
28 Lagerwaard FJ, Haasbeek CJ, Smit EF, et al. Outcomes of risk-adapted fractionated stereotactic radiotherapy for stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 03. 1. 2008;70(3):685-92. [pmid: 18164849].
29 Milano MT, Philip A, Okunieff P. Analysis of patients with oligometastases undergoing two or more curative-intent stereotactic radiotherapy courses. Int J Radiat Oncol Biol Phys. 03. 1. 2009;73(3):832-7. [pmid: 18760543].
30 Milano MT, Chen Y, Katz AW, et al. Central thoracic lesions treated with hypofractionated stereotactic body radiotherapy. Radiother Oncol. 06. 2009;91(3):301-6. [pmid: 19329210].
31 Norihisa Y, Nagata Y, Takayama K, et al. Stereotactic body radiotherapy for oligometastatic lung tumors. Int J Radiat Oncol Biol Phys. 10. 1. 2008;72(2):398-403. [pmid: 18374506].
32 Onishi H, Kuriyama K, Komiyama T, et al. Clinical outcomes of stereotactic radiotherapy for stage I non-small cell lung cancer using a novel irradiation technique: patient self-controlled breath-hold and beam switching using a combination of linear accelerator and CT scanner. Lung Cancer. 07. 2004;45(1):45-55. [pmid: 15196734].
33 Pennathur A, Luketich JD, Heron DE, et al. Stereotactic radiosurgery for the treatment of stage I non-small cell lung cancer in high-risk patients. J Thorac Cardiovasc Surg. 03. 2009;137(3):597-604. [pmid: 19258073].
34 Ricardi U, Filippi AR, Guarneri A, et al. Dosimetric predictors of radiation-induced lung injury in stereotactic body radiation therapy. Acta Oncol. 2009;48(4):571-7. [pmid: 19031164].
35 Rusthoven KE, Hammerman SF, Kavanagh BD, et al. Is there a role for consolidative stereotactic body radiation therapy following first-line systemic therapy for metastatic lung cancer? A patterns-of-failure analysis. Acta Oncol. 2009;48(4):578-83. [pmid: 19373699].
36 Rusthoven KE, Kavanagh BD, Burri SH, et al. Multi-institutional phase I/II trial of stereotactic body radiation therapy for lung metastases. J Clin Oncol. 04. 1. 2009;27(10):1579-84. [pmid: 19255320].
37 Salazar OM, Sandhu TS, Lattin PB, et al. Once-weekly, high-dose stereotactic body radiotherapy for lung cancer: 6-year analysis of 60 early-stage, 42 locally advanced, and 7 metastatic lung cancers. Int J Radiat Oncol Biol Phys. 11. 1. 2008;72(3):707-15. [pmid: 18455322].
38 Stephans KL, Djemil T, Reddy CA, et al. Comprehensive analysis of pulmonary function test (PFT) changes after stereotactic body radiotherapy (SBRT) for stage I lung cancer in medically inoperable patients. J Thorac Oncol. 07. 2009;4(7):838-44. [pmid: 19487961].
39 Takeda A, Sanuki N, Kunieda E, et al. Stereotactic body radiotherapy for primary lung cancer at a dose of 50 Gy total in five fractions to the periphery of the planning target volume calculated using a superposition algorithm. Int J Radiat Oncol Biol Phys. 02. 1. 2009;73(2):442-8. [pmid: 18990507].
40 van der Voort van Zyp NC, Prevost J-B, Hoogeman MS, et al. Stereotactic radiotherapy with real-time tumor tracking for non-small cell lung cancer: Clinical outcome. Radiother Oncol. 06. 2009;91(3):296-300. [pmid: 19297048].
41 Aoki M, Abe Y, Kondo H, et al. Clinical outcome of stereotactic body radiotherapy of 54 Gy in nine fractions for patients with localized lung tumor using a custom-made immobilization system. Radiat Med. 07. 2007;25(6):289-94. [pmid: 17634882].
42 Baumann P, Nyman J, Lax I, et al. Factors important for efficacy of stereotactic body radiotherapy of medically inoperable stage I lung cancer. A retrospective analysis of patients treated in the Nordic countries. Acta Oncol. 2006;45(7):787-95. [pmid: 16982541].
43 Brown WT, Wu X, Wen BC, et al. Early results of CyberKnife image-guided robotic stereotactic radiosurgery for treatment of lung tumors. Comput Aided Surg. 09. 2007;12(5):253-61. [pmid: 17957532].
44 Casamassima F, Masi L, Bonucci I, et al. Relevance of biologically equivalent dose values in outcome evaluation of stereotactic radiotherapy for lung nodules. Int J Radiat Oncol Biol Phys. 05. 1. 2008;71(1):145-51. [pmid: 18164855].
45 Coon D, Gokhale AS, Burton SA, et al. Fractionated stereotactic body radiation therapy in the treatment of primary, recurrent, and metastatic lung tumors: the role of positron emission tomography/computed tomography-based treatment planning. Clin Lung Cancer. 07. 2008;9(4):217-21. [pmid: 18650169].
46 Fritz P, Kraus HJ, Blaschke T, et al. Stereotactic, high single-dose irradiation of stage I non-small cell lung cancer (NSCLC) using four-dimensional CT scans for treatment planning. Lung Cancer. 05. 2008;60(2):193-9. [pmid: 18045732].
47 Guckenberger M, Heilman K, Wulf J, et al. Pulmonary injury and tumor response after stereotactic body radiotherapy (SBRT): results of a serial follow-up CT study. Radiother Oncol. 12. 2007;85(3):435-42. [pmid: 18053602].
48 Harada T, Shirato H, Ogura S, et al. Real-time tumor-tracking radiation therapy for lung carcinoma by the aid of insertion of a gold marker using bronchofiberscopy. Cancer. 10. 15. 2002;95(8):1720-7. [pmid: 12365020].
49 Hodge W, Tome WA, Jaradat HA, et al. Feasibility report of image guided stereotactic body radiotherapy (IG-SBRT) with tomotherapy for early stage medically inoperable lung cancer using extreme hypofractionation. Acta Oncol. 2006;45(7):890-6. [pmid: 16982555].
50 Hof H, Hoess A, Oetzel D, et al. Stereotactic single-dose radiotherapy of lung metastases. Strahlenther Onkol. 12. 2007;183(12):673-8. [pmid: 18040611].
51 Hof H, Muenter M, Oetzel D, et al. Stereotactic single-dose radiotherapy (radiosurgery) of early stage nonsmall-cell lung cancer (NSCLC). Cancer. 07. 1. 2007;110(1):148-55. [pmid: 17516437].
52 Hoopes DJ, Tann M, Fletcher JW, et al. FDG-PET and stereotactic body radiotherapy (SBRT) for stage I non-small-cell lung cancer. Lung Cancer. 05. 2007;56(2):229-34. [pmid: 17353064].
53 Ishimori T, Saga T, Nagata Y, et al. 18F-FDG and 11C-methionine PET for evaluation of treatment response of lung cancer after stereotactic radiotherapy. Ann Nucl Med. 12. 2004;18(8):669-74. [pmid: 15682847].
54 Joyner M, Salter BJ, Papanikolaou N, et al. Stereotactic body radiation therapy for centrally located lung lesions. Acta Oncol. 2006;45(7):802-7. [pmid: 16982543].
55 Koto M, Takai Y, Ogawa Y, et al. A phase II study on stereotactic body radiotherapy for stage I non-small cell lung cancer. Radiother Oncol. 12. 2007;85(3):429-34. [pmid: 18022720].
56 Le QT, Loo BW, Ho A, et al. Results of a phase I dose-escalation study using single-fraction stereotactic radiotherapy for lung tumors. J Thorac Oncol. 10. 2006;1(8):802-9. [pmid: 17409963].
57 Lee SW, Choi EK, Park HJ, et al. Stereotactic body frame based fractionated radiosurgery on consecutive days for primary or metastatic tumors in the lung. Lung Cancer. 06. 2003;40(3):309-15. [pmid: 12781430].
58 Muacevic A, Drexler C, Wowra B, et al. Technical description, phantom accuracy, and clinical feasibility for single-session lung radiosurgery using robotic image-guided real-time respiratory tumor tracking. Technol Cancer Res Treat. 08. 2007;6(4):321-8. [pmid: 17668940].
59 Nuyttens JJ, Prevost JB, Praag J, et al. Lung tumor tracking during stereotactic radiotherapy treatment with the CyberKnife: marker placement and early results. Acta Oncol. 2006;45(7):961-5. [pmid: 16982564].
60 Onimaru R, Fujino M, Yamazaki K, et al. Steep dose-response relationship for stage I non-small-cell lung cancer using hypofractionated high-dose irradiation by real-time tumor-tracking radiotherapy. Int J Radiat Oncol Biol Phys. 02. 1. 2008;70(2):374-81. [pmid: 18029106].
61 Paludan M, Traberg HA, Petersen J, et al. Aggravation of dyspnea in stage I non-small cell lung cancer patients following stereotactic body radiotherapy: Is there a dose-volume dependency. Acta Oncol. 2006;45(7):818-22. [pmid: 16982545].
62 Ricardi U, Guarneri A, Mantovani C, et al. Stereotactic body radiation therapy for early non-small cell lung cancer: experience at the University of Turin. J Thorac Oncol. 05. 2007;2(5 Suppl):S47. [pmid: 17457235].
63 Scorsetti M, Navarria P, Facoetti A, et al. Effectiveness of stereotactic body radiotherapy in the treatment of inoperable early-stage lung cancer. Anticancer Res. 09. 2007;27(5B):3615-9. [pmid: 17972525].
64 Sinha B, McGarry RC. Stereotactic body radiotherapy for bilateral primary lung cancers: the Indiana University experience. Int J Radiat Oncol Biol Phys. 11. 15. 2006;66(4):1120-4. [pmid: 17145532].
65 Song DY, Benedict SH, Cardinale RM, et al. Stereotactic body radiation therapy of lung tumors: preliminary experience using normal tissue complication probability-based dose limits. Am J Clin Oncol. 12. 2005;28(6):591-6. [pmid: 16317270].
66 Uematsu M, Shioda A, Suda A, et al. Computed tomography-guided frameless stereotactic radiotherapy for stage I non-small cell lung cancer: a 5-year experience. Int J Radiat Oncol Biol Phys. 11. 1. 2001;51(3):666-70. [pmid: 11597807].
67 Whyte RI, Crownover R, Murphy MJ, et al. Stereotactic radiosurgery for lung tumors: preliminary report of a phase I trial. Ann Thorac Surg. 04. 2003;75(4):1097-101. [pmid: 12683544].
68 Xia T, Li H, Sun Q, et al. Promising clinical outcome of stereotactic body radiation therapy for patients with inoperable Stage I/II non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 09. 1. 2006;66(1):117-25. [pmid: 16765528].
69 Zimmermann FB, Geinitz H, Schill S, et al. Stereotactic hypofractionated radiotherapy in stage I (T1-2 N0 M0) non-small-cell lung cancer (NSCLC). Acta Oncol. 2006;45(7):796-801. [pmid: 16982542].
70 Nakagawa K, Aoki Y, Tago M, et al. Megavoltage CT-assisted stereotactic radiosurgery for thoracic tumors: original research in the treatment of thoracic neoplasms. Int J Radiat Oncol Biol Phys. 09. 1. 2000;48(2):449-57. [pmid: 10974461].
71 Yoon SM, Choi EK, Lee SW, et al. Clinical results of stereotactic body frame based fractionated radiation therapy for primary or metastatic thoracic tumors. Acta Oncol. 2006;45(8):1108-14. [pmid: 17118847].
72 Song SY, Choi W, Shin SS, et al. Fractionated stereotactic body radiation therapy for medically inoperable stage I lung cancer adjacent to central large bronchus. Lung Cancer. 10. 2009;66(1):89-93. [pmid: 19168260].
73 Timmerman R, McGarry R, Yiannoutsos C, et al. Excessive toxicity when treating central tumors in a phase II study of stereotactic body radiation therapy for medically inoperable early-stage lung cancer. J Clin Oncol. 10. 20. 2006;24(30):4833-9. [pmid: 17050868].
74 Stephans KL, Djemil T, Reddy CA, et al. A comparison of two stereotactic body radiation fractionation schedules for medically inoperable stage I non-small cell lung cancer: the Cleveland Clinic experience. J Thorac Oncol. 08. 2009;4(8):976-82. [pmid: 19633473].
75 Timmerman R, Paulus R, Galvin J, et al. Stereotactic body radiation therapy for inoperable early stage lung cancer. JAMA. 03. 17. 2010;303(11):1070-6. [pmid: 20233825].
76 Vahdat S, Oermann EK, Collins SP, et al. CyberKnife radiosurgery for inoperable stage IA non-small cell lung cancer: 18F-fluorodeoxyglucose positron emission tomography/computed tomography serial tumor response assessment. J Hematol Oncol. 2010;3:6. [pmid: 20132557].
77 Hof H, Zgoda J, Nill S, et al. Time- and dose-dependency of radiographic normal tissue changes of the lung after stereotactic radiotherapy. Int J Radiat Oncol Biol Phys. 08. 1. 2010;77(5):1369-74. E-pub 2009 Nov 24. [pmid: 19932943].
78 Unger K, Ju A, Oermann E, et al. CyberKnife for hilar lung tumors: report of clinical response and toxicity. J Hematol Oncol. 2010;3:39. [pmid: 20969774].
79 Yamashita H, Kobayashi-Shibata S, Terahara A, et al. Prescreening based on the presence of CT-scan abnormalities and biomarkers (KL-6 and SP-D) may reduce severe radiation pneumonitis after stereotactic radiotherapy. Radiat Oncol. 2010;5:32. [pmid: 20459699].
80 Trovo M, Linda A, El NI, et al. Early and late lung radiographic injury following stereotactic body radiation therapy (SBRT). Lung Cancer. 07. 2010;69(1):77-85. [pmid: 19910075].
81 Takeda A, Ohashi T, Kunieda E, et al. Early graphical appearance of radiation pneumonitis correlates with the severity of radiation pneumonitis after stereotactic body radiotherapy (SBRT) in patients with lung tumors. Int J Radiat Oncol Biol Phys. 07. 1. 2010;77(3):685-90. [pmid: 20510193].
82 Hamamoto Y, Kataoka M, Yamashita M, et al. Local control of metastatic lung tumors treated with SBRT of 48 Gy in four fractions: in comparison with primary lung cancer. Jpn J Clin Oncol. 02. 2010;40(2):125-9. [pmid: 19825814].
83 Grills IS, Mangona VS, Welsh R, et al. Outcomes after stereotactic lung radiotherapy or wedge resection for stage I non-small-cell lung cancer. J Clin Oncol. 02. 20. 2010;28(6):928-35. [pmid: 20065181].
84 Dunlap NE, Cai J, Biedermann GB, et al. Chest wall volume receiving >30 Gy predicts risk of severe pain and/or rib fracture after lung stereotactic body radiotherapy. Int J Radiat Oncol Biol Phys. 03. 1. 2010;76(3):796-801. E-pub 2009 May 8. [pmid: 19427740].
85 Crabtree TD, Denlinger CE, Meyers BF, et al. Stereotactic body radiation therapy versus surgical resection for stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 08. 2010;140(2):377-86. [pmid: 20400121].
86 Bradley JD, El Naqa I, Drzymala RE, et al. Stereotactic body radiation therapy for early-stage non-small-cell lung cancer: the pattern of failure is distant. Int J Radiat Oncol Biol Phys. 07. 15. 2010;77(4):1146-50. [pmid: 19800181].
87 Gasent Blesa JM, Dawson LA. Options for radiotherapy in the treatment of liver metastases. Clin Transl Oncol. 10. 2008;10(10):638-45. [pmid: 18940744].
88 New England Medical Center Evidence-based Practice Center. Particle beam radiation therapies for cancer. Rockville, MD. New England Medical Center Evidence-based Practice Center. 2008:49.
89 Bucci MK, Bevan A, Roach M III. Advances in radiation therapy: conventional to 3D, to IMRT, to 4D, and beyond. CA Cancer J Clin. 03. 2005;55(2):117-34. [pmid: 15761080].
90 RT answers - external beam radiation therapy treatments. [Internet]. Fairfax (VA). American Society for Therapeutic Radiology and Oncology. accessed 2008 Aug 15. 3. Available at http://www.rtanswers.org/treatment/external_beam.htm.
91 Connell PP, Hellman S. Advances in radiotherapy and implications for the next century: a historical perspective. Cancer Res. 01. 15. 2009;69(2):383-92. [pmid: 19147546].
92 NeuroSource. Stereotactic radiosurgery: emerging trends & technology report. Chicago (IL). NeuroSource Inc. 2004:27. Also available at http://www.neurosource.com/white_papers.html.
93 Galvin JM, Bednarz G. Quality assurance procedures for stereotactic body radiation therapy. Int J Radiat Oncol Biol Phys. 05. 1. 2008;71(1 Suppl):S122-125. [pmid: 18406909].
94 García-Garduño OA, Celis MA, Lárraga-Gutiérrez JM, et al. Radiation transmission, leakage and beam penumbra measurements of a micro-multileaf collimator using GafChromic EBT film. J Appl Clin Med Phys. 2008;9(3):90-8.
95 AHA guide to the health care field. 2009 ed. Chicago IL. American Hospital Association. 2008:A15-622.
96 Chang DT, Schellenberg D, Shen J, et al. Stereotactic radiotherapy for unresectable adenocarcinoma of the pancreas. Cancer. 02. 1. 2009;115(3):665-72. [pmid: 19117351].
97 Choi BO, Choi IB, Jang HS, et al. Stereotactic body radiation therapy with or without transarterial chemoembolization for patients with primary hepatocellular carcinoma: preliminary analysis. BMC Cancer. 11. 27. 2008;8:351. [pmid: 19038025].
98 Kim MS, Yoo SY, Cho CK, et al. Stereotactic body radiation therapy using three fractions for isolated lung recurrence from colorectal cancer. Oncology. 2009;76(3):212-9. [pmid: 19218825].
99 Lee MT, Kim JJ, Dinniwell R, et al. Phase I study of individualized stereotactic body radiotherapy of liver metastases. J Clin Oncol. 04. 1. 2009;27(10):1585-91. [pmid: 19255313].
100 Olsen CC, Welsh J, Kavanagh BD, et al. Microscopic and macroscopic tumor and parenchymal effects of liver stereotactic body radiotherapy. Int J Radiat Oncol Biol Phys. 04. 1. 2009;73(5):1414-24. [pmid: 18990508].
101 Rusthoven KE, Kavanagh BD, Cardenes H, et al. Multi-institutional phase I/II trial of stereotactic body radiation therapy for liver metastases. J Clin Oncol. 04. 1. 2009;27(10):1572-8. [pmid: 19255321].
102 Schellenberg D, Goodman KA, Lee F, et al. Gemcitabine chemotherapy and single-fraction stereotactic body radiotherapy for locally advanced pancreatic cancer. Int J Radiat Oncol Biol Phys. 11. 1. 2008;72(3):678-86. [pmid: 18395362].
103 Seong J, Lee IJ, Shim SJ, et al. A multicenter retrospective cohort study of practice patterns and clinical outcome on radiotherapy for hepatocellular carcinoma in Korea. Liver Int. 2009;29(2):147-152. [pmid: 18795897].
104 Dawson LA, Eccles C, Craig T. Individualized image guided iso-NTCP based liver cancer SBRT. Acta Oncol. 2006;45(7):856-64. [pmid: 16982550].
105 Gunven P, Blomgren H, Lax I. Radiosurgery for recurring liver metastases after hepatectomy. Hepatogastroenterology. 09. 2003;50(53):1201-4. [pmid: 14571698].
106 Hoyer M, Roed H, Sengelov L, et al. Phase-II study on stereotactic radiotherapy of locally advanced pancreatic carcinoma. Radiother Oncol. 07. 2005;76(1):48-53. [pmid: 15990186].
107 Hoyer M, Roed H, Traberg HA, et al. Phase II study on stereotactic body radiotherapy of colorectal metastases. Acta Oncol. 2006;45(7):823-30. [pmid: 16982546].
108 Mendez RA, Wunderink W, Hussain SM, et al. Stereotactic body radiation therapy for primary and metastatic liver tumors: A single institution phase i-ii study. Acta Oncol. 2006;45(7):831-7. [pmid: 16982547].
109 Tse RV, Hawkins M, Lockwood G, et al. Phase I study of individualized stereotactic body radiotherapy for hepatocellular carcinoma and intrahepatic cholangiocarcinoma. J Clin Oncol. 02. 1. 2008;26(4):657-64. [pmid: 18172187].
110 Wulf J, Guckenberger M, Haedinger U, et al. Stereotactic radiotherapy of primary liver cancer and hepatic metastases. Acta Oncol. 2006;45(7):838-47. [pmid: 16982548].
111 Polistina F, Costantin G, Casamassima F, et al. Unresectable locally advanced pancreatic cancer: a multimodal treatment using neoadjuvant chemoradiotherapy (gemcitabine plus stereotactic radiosurgery) and subsequent surgical exploration. Ann Surg Oncol. 08. 2010;17(8):2092-101. E-pub 2010 Mar 12. [pmid: 20224860].
112 Kopek N, Holt MI, Hansen AT, et al. Stereotactic body radiotherapy for unresectable cholangiocarcinoma. Radiother Oncol. 01. 2010;94(1):47-52. [pmid: 19963295].
113 Mahadevan A, Jain S, Goldstein M, et al. Stereotactic body radiotherapy and gemcitabine for locally advanced pancreatic cancer. Int J Radiat Oncol Biol Phys. 11. 1. 2010;78(3):735-42. E-pub 2010 Feb 18. [pmid: 20171803].
114 Son SH, Choi BO, Ryu MR, et al. Stereotactic body radiotherapy for patients with unresectable primary hepatocellular carcinoma: dose-volumetric parameters predicting the hepatic complication. Int J Radiat Oncol Biol Phys. 11. 15. 2010;78(4):1073-80. E-pub 2010 Mar 6. [pmid: 20207492].
115 Yang ZX, Wang D, Wang G, et al. Clinical study of recombinant adenovirus-p53 combined with fractionated stereotactic radiotherapy for hepatocellular carcinoma. J Cancer Res Clin Oncol. 04. 2010;136(4):625-630. [pmid: 19882171].
116 Seo YS, Kim MS, Yoo SY, et al. Preliminary result of stereotactic body radiotherapy as a local salvage treatment for inoperable hepatocellular carcinoma. J Surg Oncol. 09. 1. 2010;102(3):209-214. [pmid: 20740576].
117 Louis C, Dewas S, Mirabel X, et al. Stereotactic radiotherapy of hepatocellular carcinoma: preliminary results. Technol Cancer Res Treat. 10. 2010;9(5):479-487. [pmid: 20815419].
118 Stintzing S, Hoffmann RT, Heinemann V, et al. Radiosurgery of liver tumors: value of robotic radiosurgical device to treat liver tumors. Ann Surg Oncol. 11. 2010;17(11):2877-2883. [pmid: 20574773].
119 Stintzing S, Hoffmann RT, Heinemann V, et al. Frameless single-session robotic radiosurgery of liver metastases in colorectal cancer patients. Eur J Cancer. 04. 2010;46(6):1026-1032. [pmid: 20153959].
120 Shin YJ, Kim MS, Yoo SY, et al. Pilot study of stereotactic body radiotherapy for huge hepatocellular carcinoma unsuitable for other therapies. Tumori. 01. 2010;96(1):65-70. [pmid: 20437860].
121 Goodman KA, Wiegner EA, Maturen KE, et al. Dose-escalation study of single-fraction stereotactic body radiotherapy for liver malignancies. Int J Radiat Oncol Biol Phys. 10. 1. 2010;78(2):486-493. [pmid: 20350791].
122 Cardenes HR, Price TR, Perkins SM, et al. Phase I feasibility trial of stereotactic body radiation therapy for primary hepatocellular carcinoma. Clin Transl Oncol. 03. 2010;12(3):218-225. [pmid: 20231127].
123 Gerszten PC, Ozhasoglu C, Burton SA, et al. CyberKnife frameless single-fraction stereotactic radiosurgery for tumors of the sacrum. Neurosurg Focus. 08. 15. 2003;15(2):E7. [pmid: 15350038].
124 Kim MS, Choi C, Yoo S, et al. Stereotactic body radiation therapy in patients with pelvic recurrence from rectal carcinoma. Jpn J Clin Oncol. 10. 2008;38(10):695-700. [pmid: 18723850].
125 Kunos C, von Gruenigen V, Waggoner S, et al. Cyberknife radiosurgery for squamous cell carcinoma of vulva after prior pelvic radiation therapy. Technol Cancer Res Treat. 10. 2008;7(5):375-80. [pmid: 18783287].
126 Guckenberger M, Bachmann J, Wulf J, et al. Stereotactic body radiotherapy for local boost irradiation in unfavourable locally recurrent gynaecological cancer. Radiother Oncol. 01. 2010;94(1):53-9. [pmid: 20079550].
127 Jorcano S, Molla M, Escude L, et al. Hypofractionated extracranial stereotactic radiotherapy boost for gynecologic tumors: a promising alternative to high-dose rate brachytherapy. Technol Cancer Res Treat. 10. 2010;9(5):509-14. [pmid: 20815422].
128 Svedman C, Karlsson K, Rutkowska E, et al. Stereotactic body radiotherapy of primary and metastatic renal lesions for patients with only one functioning kidney. Acta Oncol. 2008;47(8):1578-83. [pmid: 18607859].
129 Beitler JJ, Makara D, Silverman P, et al. Definitive, high-dose-per-fraction, conformal, stereotactic external radiation for renal cell carcinoma. Am J Clin Oncol. 12. 2004;27(6):646-8. [pmid: 15577450].
130 Katoh N, Onimaru R, Sakuhara Y, et al. Real-time tumor-tracking radiotherapy for adrenal tumors. Radiother Oncol. 06. 2008;87(3):418-24. [pmid: 18439693].
131 Ponsky LE, Mahadevan A, Gill IS, et al. Renal radiosurgery: initial clinical experience with histological evaluation. Surg Innov. 12. 2007;14(4):265-9. [pmid: 18178914].
132 Svedman C, Sandstrom P, Pisa P, et al. A prospective Phase II trial of using extracranial stereotactic radiotherapy in primary and metastatic renal cell carcinoma. Acta Oncol. 2006;45(7):870-5. [pmid: 16982552].
133 Chawla S, Chen Y, Katz AW, et al. Stereotactic body radiotherapy for treatment of adrenal metastases. Int J Radiat Oncol Biol Phys. 09. 1. 2009;75(1):71-75. [pmid: 19250766].
134 Fuller DB, Naitoh J, Lee C, et al. Virtual HDR CyberKnife treatment for localized prostatic carcinoma: dosimetry comparison with HDR brachytherapy and preliminary clinical observations. Int J Radiat Oncol Biol Phys. 04. 1. 2008;70(5):1588-1597. [pmid: 18374232].
135 Madsen BL, Hsi RA, Pham HT, et al. Stereotactic hypofractionated accurate radiotherapy of the prostate (SHARP), 33.5 Gy in five fractions for localized disease: first clinical trial results. Int J Radiat Oncol Biol Phys. 03. 15. 2007;67(4):1099-1105. [pmid: 17336216].
136 Townsend NC, Huth BJ, Ding W, et al. Acute toxicity after CyberKnife-delivered hypofractionated radiotherapy for treatment of prostate cancer. Am J Clin Oncol. 02. 2011;34(1):6-10. E-pub 2010 Jan 8. [pmid: 20065849].
137 Freeman DE, King CR. Stereotactic body radiotherapy for low-risk prostate cancer: five-year outcomes. Radiat Oncol. 01. 10. 2011;6(1):3. [pmid: 21219625].
138 Aluwini S, van RP, Hoogeman M, et al. CyberKnife stereotactic radiotherapy as monotherapy for low- to intermediate-stage prostate cancer: early experience, feasibility, and tolerance. J Endourol. 05. 2010;24(5):865-869. [pmid: 20433370].
139 Bolzicco G, Favretto MS, Scremin E, et al. Image-guided stereotactic body radiation therapy for clinically localized prostate cancer: preliminary clinical results. Technol Cancer Res Treat. 10. 2010;9(5):473-477. [pmid: 20815418].
140 Oermann EK, Slack RS, Hanscom HN, et al. A pilot study of intensity modulated radiation therapy with hypofractionated stereotactic body radiation therapy (SBRT) boost in the treatment of intermediate- to high-risk prostate cancer. Technol Cancer Res Treat. 10. 2010;9(5):453-462. [pmid: 20815416].
141 Kim JH, Kim MS, Yoo SY, et al. Stereotactic body radiotherapy for refractory cervical lymph node recurrence of nonanaplastic thyroid cancer. Otolaryngol Head Neck Surg. 03. 2010;142(3):338-43. [pmid: 20172377].
142 Choi CW, Cho CK, Yoo SY, et al. Image-guided stereotactic body radiation therapy in patients with isolated para-aortic lymph node metastases from uterine cervical and corpus cancer. Int J Radiat Oncol Biol Phys. 05. 1. 2009;74(1):147-53. [pmid: 18990511].
143 McCammon R, Schefter TE, Gaspar LE, et al. Observation of a dose-control relationship for lung and liver tumors after stereotactic body radiation therapy. Int J Radiat Oncol Biol Phys. 01. 1. 2009;73(1):112-8. [pmid: 18786780].
144 Ernst-Stecken A, Lambrecht U, Mueller R, et al. Hypofractionated stereotactic radiotherapy for primary and secondary intrapulmonary tumors: first results of a phase I/II study. Strahlenther Onkol. 12. 2006;182(12):696-702. [pmid: 17149575].
145 Jereczek-Fossa BA, Kowalczyk A, D’Onofrio A, et al. Three-dimensional conformal or stereotactic reirradiation of recurrent, metastatic or new primary tumors. Analysis of 108 patients. Strahlenther Onkol. 01. 2008;184(1):36-40. [pmid: 18188521].
146 Nuyttens JJ, Prevost JB, Van der Voort van Zijp NC, et al. Curative stereotactic robotic radiotherapy treatment for extracranial, extrapulmonary, extrahepatic, and extraspinal tumors: technique, early results, and toxicity. Technol Cancer Res Treat. 12. 2007;6(6):605-10. [pmid: 17994790].
147 Shioyama Y, Nakamura K, Anai S, et al. Stereotactic radiotherapy for lung and liver tumors using a body cast system: setup accuracy and preliminary clinical outcome. Radiat Med. 09. 2005;23(6):407-13. [pmid: 16389982].
148 Teh BS, Paulino AC, Lu HH, et al. Versatility of the Novalis system to deliver image-guided stereotactic body radiation therapy (SBRT) for various anatomical sites. Technol Cancer Res Treat. 08. 2007;6(4):347-354. [pmid: 17668943].
149 Wulf J, Hadinger U, Oppitz U, et al. Stereotactic radiotherapy of targets in the lung and liver. Strahlenther Onkol. 12. 2001;177(12):645-655. [pmid: 11789403].
150 Milano MT, Katz AW, Okunieff P. Patterns of recurrence after curative-intent radiation for oligometastases confined to one organ. Am J Clin Oncol. 04. 2010;33(2):157-163. E-pub 2009 Sep 18. [pmid: 19770627].
151 Kang JK, Kim MS, Kim JH, et al. Oligometastases confined one organ from colorectal cancer treated by SBRT. Clin Exp Metastasis. 04. 2010;27(4):273-278. [pmid: 20373133].
152 Dictionary of cancer terms: Karnofsky performance status [Internet]. Bethesda MD. National Cancer Institute. accessed 2008 Dec 2. 1. Available at http://www.nci.nih.gov/Templates/db_alpha.aspx?CdrID=44156.
153 ISD data dictionary: WHO/ECOG performance status [Internet]. Edinburgh, Scotland. ISD Scotland. accessed 2008 Dec 2. 1. Available at http://www.datadictionaryadmin.scot.nhs.uk/isddd/11888.html.
154 Emara K, Weisbrod DJ, Sahgal A, et al. Stereotactic radiotherapy in the treatment of juxtapapillary choroidal melanoma: preliminary results. Int J Radiat Oncol Biol Phys. 05. 1. 2004;59(1):94-100. [pmid: 15093904].
155 Miralbell R, Caro M, Weber DC, et al. Stereotactic radiotherapy for ocular melanoma: initial experience using closed eyes for ocular target immobilization. Technol Cancer Res Treat. 10. 2007;6(5):413-417. [pmid: 17877429].
156 Collins BT, Erickson K, Reichner CA, et al. Radical stereotactic radiosurgery with real-time tumor motion tracking in the treatment of small peripheral lung tumors. Radiat Oncol. 2007;2:39. [pmid: 17953752].
157 Gerszten PC, Burton SA, Belani CP, et al. Radiosurgery for the treatment of spinal lung metastases. Cancer. 12. 1. 2006;107(11):2653-61. [pmid: 17063501].
158 Benedict SH, Yenice KM, Followill D, et al. Stereotactic body radiation therapy: the report of the AAPM Task Group 101. Med Phys. 08. 2010;37(8):4078-101. [pmid: 20879569].