# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

Mark K. Buyyounouski, M.D, M.S.

Radiation Oncologist

Fox Chase Cancer Center

Philadelphia, PA19111

Brian D. Kavanagh, M.D, M.P.H.

Radiation Oncologist

University of Colorado Hospital

Aurora, CO 80045

Robert Phillips, Ph.D.

Chief, Radiology Devices Branch

Food and Drug Administration

Silver Spring, MD20993

Louis Potters, M.D., F.A.C.R.

Chairman, Department of Radiation Medicine

North Shore-LIJ Health System

New Hyde Park, NY 11040

Michael Steinberg, M.D., F.A.S.T.R.O., F.A.C.R., F.A.C.R.O.

Professor and Chair, Department of Radiation Oncology

David Geffen School of Medicine at UCLA

Los Angeles, CA90095