# Methods

## Literature Searches

Narrative review articles and gray literature searches were used to address Guiding Questions 1 and 2. We searched the Internet for gray literature applicable to the Background section, Guiding Question 1 and Guiding Question 2. We performed the Internet searches in the Google search engine, and visited relevant links within the first 10 pages of search results. Gray literature was also searched within Windhover, Current HC News,” Gray Sheet, The Wall Street Journal, and Clinica. We also visited association and organization Web sites (e.g., International RadioSurgery Association), and Web sites posted within the organization’s site. Information regarding instrumentation was captured by a search of the manufacturers’ Websites and a search of the Food and Drug Administration’s (FDA) Center for Devices and Radiological Health (CDRH) (http://www.fda.gov/cdrh/). Instrumentation information can be found in Appendix F, Currently Marketed Devices for SBRT. Additional information on device specifications and compatible accessories was obtained through interviews with manufacturers (Appendix N).

A systematic scan of the published medical literature was performed to address Guiding Question 3. Our search strategy involved Ovid, MEDLINE, EMBASE, the Cochrane Database, and the Health Technology Assessment Database. ECRI Institute’s biomedical engineers and medical physicists suggested confining our searches to the past five to eight years given the technology changes. (There are reports in the literature as far back as 1993 for the use of SRS for ocular melanoma.)Given that this is a Technical Brief, our search range was limited to January 2000 through December 2010. The full search strategy can be found in Appendix A, Literature Search Methods.

## Study Eligibility

The titles of the citations identified through the literature searches were screened for relevance to the topic. Articles with titles that seemed potentially relevant were then passed to the abstract-screening level. Abstracts were initially screened in duplicate (first 50 abstracts) by two reviewers to determine relevance for SBRT. Duplicate review was used as a quality control measure to determine inter-rater agreement in regard to the questions asked about the retrieved abstracts. After screening the first 50 abstracts in duplicate, both reviewers understood the questions and proceeded to screen subsequent abstracts individually. All relevant abstracts were ordered as full-text articles for further review. Again, the first 50 full-text articles were screened in duplicate to determine eligibility for data extraction, and subsequent articles were screened individually. Eligible studies were clinical studies of any design, studies in English, patient population of at least three patients, the use of SBRT, and with treatments delivered in 10 or fewer fractions. Studies not eligible for data extraction included treatment planning (e.g., dosing), treatment delivery (e.g., accuracy), nonmalignant tumors, the use of more than 10 treatment fractions, and fewer than three patients.

## Data Extraction

SRS 4.0 (Mobius Analytics, Ottawa, Canada) was used for the data extraction process. If reported, the information extracted included: country of study, year of study, authors, study design, type of cancer, patient inclusion/exclusion criteria, comparators, size of patient population, sex and age of patients, prior or concurrent treatment, instrumentation and type of radiation used (x-ray photons), algorithms, quality assurance and/or training procedures, tumor quantity and tumor size, total radiation dosage, number of fractions and dose of each fraction, length of followup, outcomes measured and how they were measured, and adverse events/harms.

## Summary of Items of Interest

For Guiding Question 3, we organized the relevant literature by study design into two tables. Each table is arranged by year of publication (most recent year first) and then alphabetically by author. These tables include the following information: author, year, cancer type, instrumentation/algorithms, study design/study size, prior/concurrent treatment, length of followup, outcomes measured, and adverse events. The tables can be found in Appendix L, Results for Guiding Question 3. The cancer types found within the literature include lung/thorax, colon, liver, pancreas, kidney, pelvic, sacrum, uterus, thyroid, and prostate.

## Software

To calculate overall means and medians for patient ages and lengths of followup, we used Microsoft Office Excel 2007 (Microsoft Corporation, Redmond, WA).17