# Conclusion

In brief, there are many publications on SBRT for the treatment of cancer, principally cancer involving the lung. None of the currently available studies include comparison groups. Comparative studies (preferably randomized trials, but at the least, trials with concurrent controls) are needed to provide convincing evidence that the theoretical advantages of SBRT over other radiotherapies actually occur in the clinical setting. At present, there is only one small ongoing trial making such a comparison. Consequently, a full systematic review of the current literature cannot answer questions on the effectiveness and safety of SBRT compared to other radiotherapy interventions. Two large ongoing trials scheduled for completion in 2013 have the potential to answer questions about the effectiveness and safety of SBRT as compared to surgical resection in resectable early-stage lung cancer.