# Appendixes

Appendix A Literature Search Methods

Appendix B Included Studies

Appendix C Excluded Studies

Appendix D Personnel Qualifications

Appendix E Recommendations

Appendix F Currently Marketed Devices for SBRT

Appendix G Linac-Based SBRT Accessories

Appendix H Applicants’ FDA 510K Information

Appendix I Manufacturer Web Sites

Appendix J Facilities Performing SBRT for Solid Tumors

Appendix K Ongoing Clinical Trials

Appendix L Results for Guiding Question 3

Appendix M Literature Results Device Specifications

Appendix N Responses From Device Manufacturers on Device Specifications and Compatible Accessories (January 2010)

Appendix O References Cited in Appendixes