# Manufacturer Web Sites

Manufacturers

Company | Web site
Accuray Incorporated572 | http://www.accuray.com
BrainLAB AG573 | http://www.brainlab.com http://www.poweringhope.com
Direx Systems Corp.574 | http://www.direxusa.com
Elekta Inc.575 | http://www.elekta.com
MHI Medical Systems Inc.576 | http://www.mhi.co.jp/en/index.html
Radionics577 | http://www.radionics.com
Siemens USA578 | http://www.medical.siemens.com
TomoTherapy Incorporated579 | http://www.tomotherapy.com
Varian Medical Systems580 | http://www.varian.com