# Applicants’ FDA 510K Information

Regulatory Status of Devices

Device Name | Manufacturer/Distributor | 510(k) Applicant | Substantial Equivalence | Classification Name | Product Code(s) | 510(k) Number | Approval Date
AccuChanger 549 | Direx Systems Corporated | Direx Systems Corp. | AccuLeaf; Cranial stereotactic equipment k010065 Arplay/BrainLAB; Radionics XKnife^*^ | Accelerator, Linear, Medical | IXI | K043409 | 05/05
AccuLeaf 550 | Direx Systems Corporated | Direx Systems Corp. | BrainLAB MMLC^*^ | Accelerator, Linear, Medical | IXI | K040553 | 04/04
Axesse™ | Elekta Inc. | | | Approval documentation requested from FDA and manufacturer
Beam Modulator™ 551 | Elekta Inc. | Elekta Ltd. | Millenium MLC (now Varian’s HD 120 MLC); Moduleaf MLC (Siemens) | Radiation therapy beam-shaping block | 90 IYE and IXI | K042794 | 01/05
CyberKnife® Robotic Radiosurgery System 552 | Accuray Incorporated | Accuray Corporation | Predicate device | Medical charged particle radiotherapy device | IYE | K072504 | 09/07
Dynamic Micro Multileaf Collimator (DMMLC) 553 | Elekta Limited | Elekta Limited | Predicate device | Medical Linear Accessory, IYE | IYE | K082122 | 08/08
HD 120 MLC 554 | Varian Medical Systems | Varian Medical Systems | Predicate device | Medical Charged Particle Radiation Therapy System | 90 IYE | K071992 | 08/07
Leksell Gamma Knife® Perfexion™ 555 | Elekta Inc. | Elekta Ltd. | Predicate device | Radionuclide radiation therapy system | IWB | K063512 | 03/07
m3^®^ (micro-Multileaf Collimator) 556 | BrainLAB AG | BrainLAB AG | Predicate device | Accelerator, Linear, Medical | 90 IYE | K020860 | 06/02
MHI-TM2000 557 | MHI Medical Systems/Hiroshima Machinery Works | Mitsubishi Heavy Industries, Ltd. | Trilogy; Hi-Art System | Accelerator, Linear, Medical | IYE | K072047 | 08/07
Micro MLC 558 | Siemens Medical Solutions USA, Inc. | Siemens Medical Solutions | Predicate device | Accelerator, Linear, Medical | IXI | K032790 | 10/03
Moduleaf™ mini Multileaf Collimator 559 | Siemens Medical Solutions | MRC Systems GmbH | Predicate device | Block, Beam Shaping, Radiation Therapy | 90 IXI | K030609 | 03/03
Novalis TX™ 554,560–562 | BrainLAB AG/Varian Medical Systems | BrainLAB AG/Varian Medical Systems | | | Trilogy – 90 IYE | Trilogy – K081188 | 07/08
Novalis TX™ 554,560–562 | BrainLAB AG/Varian Medical Systems | BrainLAB AG/Varian Medical Systems | | | HD120–90 IYE | HD120-K071992 | 08/07
Novalis TX™ 554,560–562 | BrainLAB AG/Varian Medical Systems | BrainLAB AG/Varian Medical Systems | | | ETX™ (Exac- Trac) – IYE | ETX – K072046 | 10/07
Novalis TX™ 554,560–562 | BrainLAB AG/Varian Medical Systems | BrainLAB AG/Varian Medical Systems | | | OBI – 90 IYE | OBI – K042720 | 10/04
Oncor Artiste, Impression, Avant-Garde, and Expression 563–565 | Siemens Healthcare | Siemens Medical Solutions USA, Inc. | ONCOR linac family | Accelerator, Linear, Medical | IYE | Artiste – K072485 | 12/07
Oncor Artiste, Impression, Avant-Garde, and Expression 563–565 | Siemens Healthcare | Siemens Medical Solutions USA, Inc. | ONCOR linac family | Accelerator, Linear, Medical | IYE | Avant-Garde – K031764 | 03/06
Oncor Artiste, Impression, Avant-Garde, and Expression 563–565 | Siemens Healthcare | Siemens Medical Solutions USA, Inc. | ONCOR linac family | Accelerator, Linear, Medical | IYE | Expression – K060226 | 09/03
Synergy®S 566 | Elekta | Elekta Limited | Predicate device | Medical Linear Accelerator Accessory 90 IYE | 90 IYE | K051932 | 08/05
TomoTherapy® Hi-Art® 567–570 | TomoTherapy, Inc. | TomoTherapy, Inc. | Varian Clinac 600^*^ | Medical charged- particle radiation therapy system | MUJ | K082005 | 08/08
TomoTherapy® Hi-Art® 567–570 | TomoTherapy, Inc. | TomoTherapy, Inc. | Varian Clinac 600^*^ | Medical charged- particle radiation therapy system | MUJ | K060912 | 04/06
TomoTherapy® Hi-Art® 567–570 | TomoTherapy, Inc. | TomoTherapy, Inc. | Varian Clinac 600^*^ | Medical charged- particle radiation therapy system | MUJ | K042739 | 11/04
TomoTherapy® Hi-Art® 567–570 | TomoTherapy, Inc. | TomoTherapy, Inc. | Varian Clinac 600^*^ | Medical charged- particle radiation therapy system | MUJ | K013673 | 01/02
Trilogy™ 560 | Varian Medical Systems | Varian Medical Systems | BrainLAB Novalis® Shaped Beam Surgery System; Varian Medical Systems’ Clinac 2300 C/D | Medical charged- particle radiation therapy system | 90 IYE | K081188 | 07/08
XKnife™ MMLC™ 571 (Miniature multi-leaf collimator) | Radionics | Radionics | | Radiotherapy beam shaping block | 90 IYE | K993594 Asked Radionics to confirm | 12/99

* Purged from CDRH database

CDRH: Center for Devices and Radiological Health

HD: High definition

MLC: Multi-leaf collimator

MMLC: Micro multi-leaf collimator

NR: Not reported