# Linac-Based SBRT Accessories

Linac Accessories

Device Name | Manufacturer/Distributor | Description | Dedicated to SRS | FDA Indications | Indications Presented on Company Web site | Compatibility
AccuChanger | Direx Systems Corporated | A linac-mounted, computer-controlled, fully automated collimator changer for multi arc or step-and-shoot cone based SRS. A unique fixed arrangement of multi-sized taped tungsten cones provides for fast and precise changing and positioning of the collimators. The available 16 circular fields, with diameters in the range of 4 mm to 34 mm in 2 mm steps, enable sharp radiosurgical delivery. | Yes | Collimation of megavoltage photon beams in conjunction with SRS and SRT treatments. | NR | Various linacs
AccuLeaf | Direx Systems Corporated | A computer controlled, video-guided micro multi-leaf collimator (MMLC). A unique two-level perpendicular leaf configuration, with a field size of approximately 100 mm × 110 mm, reduces effective leaf thickness and achieves a higher resolution, low leakage collimator for both conformal shaping and IMRT/IMSRS delivery. | No | Enables irregular field’s treatments to be performed with finely shaped patterns; performs the same function as customized beam shaping blocks, and circular or cut blocks collimators. | NR | Various linacs
Beam Modulator™ | Elekta Inc. | Integrated multi-leaf collimator with a generous 16 × 21 cm field size. The field comprises 80 individually controlled leaves, each with a travel range of more than 21 cm. Because opposing leaves can pass each other (interdigitate), clinicians can create a range of finely shaped, high-resolution fields simultaneously within one field. This contributes to improved conformal avoidance of critical structures. The integrated design means no compromise in clearance for conventional and noncoplanar beams. | No | X-ray collimator, used with the Elekta range of medical linacs; intended to assist a licensed practitioner in the delivery of radiation in single or multiple fractions to defined target volumes anywhere in the body (e.g., lesions, AVMs, malignant and benign tumors) sparing surrounding normal tissue and critical organs from excess radiation. | NR | Elekta linacs
Dynamic Micro Multileaf Collimator (DMMLC) | Elekta Inc. | 3 dynamic micro multileaf add-on collimators: a 3 mm, 5 mm and 7 mm leaf width (at isocenter) and 7×7, 10×12, and 10×17 field size (at isocenter) respectively. All options offer the facility for dynamic treatments and the improved homogeneity in target shaping, including minimizing dose to critical organs. The 3 mm and 5 mm DMMLCs are certified for use up to 18 MV making it an extremely versatile tool for SRT and SRS. To optimize beam shaping provided by the Elekta add on DMMLC, the leaves have been designed to be dual focused, minimizing and homogenizing the penumbra. Leakage and unwanted dose outside the target area is limited by the unique design of the leaves and the 8 cm leaf height. | No | Indicated for use when additional flexibility is required in conforming the radiation beam to the anatomy to be exposed. | NR | Elekta and a range of linacs from other vendors
HD 120 MLC | Varian Medical Systems | HD120 provides 120 interleaved leaves: 64 – 2.5 mm centrally located 56 – 5 mm peripherally with a fixed treatment field of 22 cm × 40 cm and a modulated field of 22 cm × 32 cm., Output – 1,000 MU/min at 100 cm. Options: Gating – Real Time Position Management; Aria. | No | Target volumes during RS and RT | | Varian’s Trilogy
m3^®^ (micro-Multileaf Collimator) | BrainLAB AG | The m^3^ is a therapeutic collimator. It comprises multiple motorized tungsten leafs, which are suited to shaping specific therapeutic X-ray fields, both in a static fashion as well as dynamically via leaf-movement during treatment. | No | In conjunction with Elekta and GE Linacs, the m^3^ performs with same function as customized shadow blocks or stereotactic collimators. This standard configuration is suitable for static conformal treatments and “step and shoot IMRT”. The advanced m^3^ Siemens integration feature available for Siemens Linacs allows additionally to perform “dynamic arc” and automated “step and shoot IMRT” treatments with the m^3^. The advanced Varian integration feature available for Varian Linacs allows to perform “dynamic arc” and “dynamic IMRT” treatments with the m^3^. | To accommodate a higher-resolution dose delivery, new multileaf collimator designs with 5 mm thick leaves allow the delivery of fractionated SRS, but are not generally acceptable for single-fraction radiosurgery. For radiosurgery, the recommended limit for dose gradient in the beam penumbra (from 80% to 20%) is greater than or equal to 60%/3 mm. The m^3^ with its 3 mm-thin leaves has an effective penumbra of less than 3 mm for all SRS field sizes and meets all SRS requirements. | Elekta, GE, Siemens, Varian
micro MLC | Siemens Medical Solutions USA Inc. | The microMLC is a conformal RT and RS device that is mounted to a standard RT linac. The microMLC receives input from planning-system software that determines the collimator aperture shapes at different gantry positions along the arc around the target area. Radiation is delivered at a constant rate. | No | The microMLC is a conformal RT and RS device that delivers a shaped x-ray beam from a RT source. The microMLC is attached to a linac and consists of a series of pairs of tungsten leaves that collimate the radiation delivery to a target based on a treatment plan generated by planning software. The device is used to assist the clinician in the delivery of well-defined target volumes of radiation while sparing the surrounding tissues and organs.
ModuLeaf™ Mini Multileaf Collimator | Siemens Medical Solutions | Features of the ModuLeaf™ include: 2.5 mm width at the isocenter, 80 leaves, 10 cm × 12 cm maximum field size at isocenter | No | A conformal RT and RS device that delivers a shaped X-ray beam from a RT source. The ModuLeaf is attached to a linac and consists of pairs of tungsten leaves that collimate the radiation delivery to a target based on a treatment plan generated by planning software. The device is used to help the clinician deliver well-defined target volumes of radiation while sparing the surrounding tissues and organs. | Extracranial target volumes where highest precision is required | Major linac systems
XKnife™MMLC™ | Radionics | A complete system consisting of an independent device that attaches to a Siemens linac for small field conformal radiosurgery or radiotherapy. | | The delivery of radiation to well-defined target volumes while sparing surrounding normal tissue and critical organs from excess radiation. With Radionics’ XPlan Conformal Treatment Planning Software or any treatment- planning system, the MMLC enables static conformal treatments to be performed with finely shaped field patterns. In this application, the MMLC performs the same function as customized beam shaping blocks, and circular or cut block collimators. | Spine and other sites | Siemens and a variety of other linacs

AVM: Arteriovenous malformation

cm: Centimeter

DMMLC: Dynamic Micro Multileaf Collimator

FDA: United States Food and Drug Administration

HD: High definition

IMRT: Intensity modulated radiation therapy

IMSRS: Intensity modulated stereotactic radiosurgery

mm: Millimeter

MMLC: Micro multi-leaf collimator

MU/min: Monitor units per minute

MV: Megavolts

NR: Not reported

RS: Radiosurgery

RT: Radiotherapy

SRS: Stereotactic radiosurgery

SRT: Stereotactic radiotherapy