# Currently Marketed Devices for SBRT

Devices Currently Marketed for Stereotactic Body Radiation Therapy

Device Name | Manufacturer/Distributor | Features | Dedicated to SRS | FDA Indication | Extracranial Indications Presented on Company Web site
Axesse™ | Elekta | ✓ Beam delivery – wide range of noncoplanar angles; ✓ Beam energy – multiple energy (photon); ✓ Collimation – MLC; ✓ Design – image-guided robotic linac that combines high-conformance beam shaping with 4D Adaptive™ IGRT technology; ✓ Dose delivery – multiple energy choices; ✓ Imaging – CT/MR imaging with patient in immobilization (no fiducials necessary); ✓ Patient Positioning/Localization – BodyFIX dual vacuum-activated immobilization and fixation system; automatic reposition in up to 6 degrees of freedom; ✓ Treatment Sessions – single and fractionated | No | No response from FDA or manufacturer | Spinal metastases, lung, liver, prostate, head, neck
CyberKnife® robotic radiosurgery system | Accuray Incorporated | ✓ Beam delivery – noncoplanar and nonisocentric; anterior beam delivery; ✓ Beam energy – 6 MV nominal (photon); ✓ Collimation – 12 fixed apertures; Xchange™ Robotic Collimator Changer automatically exchanges collimators; ✓ Design – a treatment radiation generator, linear accelerator, manipulator (robot) with six degrees of freedom, and a target locating subsystem; ✓ Dose delivery – A 6 MV X-band linac; ✓ Field size – determined by the use of interchangeable secondary circular cones with diameters ranging from 5.0 to 60.0 mm; ✓ Imaging – continuously delivers imaging to ensure target accuracy throughout the entire treatment; InTempo™ Adaptive Imaging System tracks and corrects for intra-fraction prostate motion; ✓ Output – available at 800 MU/min at 80 cm, 600 MU/min, and 400 Mu/min; ✓ Patient Positioning/Localization – only radiosurgery system to move to and with the patient; room-based stereo x-ray with 2D kV-kV match; ✓ Tracking – Fiducial tracking, Xsight™ Spine Tracking, Xsight™ Lung Tracking, and Synchrony™ Respiratory Tracking for dynamic positioning and pointing of the linac; ✓ Treatment Sessions – single and fractionated | Yes | Treatment planning and image-guided SRS and precision RT for lesions, tumors and conditions anywhere in the body | Spine, lung, liver, prostate, pancreas, kidney, head, neck
Leksell Gamma Knife^®^ Perfexion™ | Elekta Inc. | ✓ Beam delivery – 192 cobalt-60 sources housed in the central body of the unit produce 192 collimated beams directed to a single focal point (isocenter); ✓ Collimation – 4,8, 16 mm diameter; ✓ Design – a radiation unit with patient-positioning system and an operator console; ✓ Dose delivery – multiple converging fixed beams of ionizing radiation; ✓ Imaging – MRI/CT prior to treatment; ✓ Output – >3 Gy/min; ✓ Patient Fixation – head fixated in the Leksell® Stereotactic Frame. Awaiting approval on re-locatable frame.; ✓ Total cobalt-60 activity at loading (approximate) – <6,300 Curie (2.33 × 10^14^ Bq); ✓ Treatment Sessions – single with availability of fractionated upon approval of Extend™ program | No | Metastatic tumors, and head structure targets (a few millimeters to several centimeters) | Cervical spine, head, neck, larynx tumors
MHI-TM2000 Linear Accelerator System | Mitsubishi Heavy Industries (MHI) | ✓ Beam delivery – Gimballed x-ray irradiation offers tilt and pan-rotation functions enabling fine adjustments in any direction; ✓ Collimation – MLC; ✓ Design – O-ring-shaped mechanical structure provides a high level of rigidity; X-ray generator incorporates a compact accelerator tube; ✓ Image Processing System – ExacTrac 3rd Party by BrainLAB (K072046 approved by FDA on 8/07); ✓ Treatment Sessions – single and fractionated | No | Radiation therapy of lesions, tumors and conditions anywhere in the body | NR
Novalis TX™ | BrainLAB/Varian Medical Systems | ✓ Accuracy - millimeter precision utilizing BrainLAB’s iPlan and ExacTrac technologies; ✓ Beam delivery – fixed beam positions and continuous arc delivery with RapidArc; anterior beam delivery and full 180 degree posterior beams; ✓ Beam energy – 6–20 MV/6–20MEV; ✓ Collimation –Varian’s HD120 MLC 120 interleaved ultra thin collimators provides 2.5 mm collimation at isocenter and 5.0 mm collimations at the periphery.; ✓ Design – includes Adaptive Gating and On-Board Imager devices; ✓ Field size – 22 × 40 cm maximum; ✓ Imaging – ExacTrac and x-ray 6D and Snap Verification; ✓ Output – 1,000 MU at 100 cm; ✓ Patient positioning/localization – 6D Robotic couch top, Varian Exact^®^ couch; ✓ Treatment Sessions – single and fractionated | Yes | The Varian High Energy linear accelerator is intended to provide SRS and precision RT for lesions, tumors and conditions anywhere in the body | Spine, lung, liver, prostate, head, neck
Oncor ARTISTE, Impression, Avant-Garde, Expression | Siemens | Artiste; ✓ Beam energy – 6 MV (photon); ✓ Collimation – 160 leaf MLC; ✓ Design – includes an Electronic Portal Imaging Device (EPID), a 160 leaf MLC, and the syngo™ RT Therapist Express Workspace with MVision™; ✓ Imaging – OPTIVUE 1000ART amorphous silicon (a-Si) portal imaging system; ✓ Patient-positioning verification – use of the OPTIVUE imaging system, including MVision™ Megavoltage Cone Beam (MVCB) Imaging and/or CTVision; ✓ Respiratory Gating – ANZAI breathing belt system; Impression/Avant-Garde/Expression; ✓ Beam energy – 6/10 MV photon/6–21 MeV; ✓ Collimation – OPTIFOCUS 82 leaf MLC (static and dynamic modes); ✓ Field size – 40 cm × 40 cm fully-conformal; ✓ Imaging OPTIVUE 1000/ST electronic portal imaging device (EPID) and MVision™ megavoltage cone beam on-board imaging; ✓ Output – 200–500 MU/min, special configuration-1,000 MU/min for maximum 5 × 5 cm field (Avant-Garde); 200–300 MU/min, special configuration-500 MU/min for maximum 5 ×5 field; ✓ Patient position localization and setup – Adaptive Targeting™ supports alignment of 3D planning data with newly acquired 3D Cone Beam data; ✓ Respiratory Gating – standard on Avant-Garde/optional on Impression | No | The delivery of x-ray radiation for therapeutic treatment of cancer. | Head, neck, extracranial areas
Synergy®S | Elekta Inc. | ✓ Beam delivery – a 62 cm treatment head in combination with industry best isocenter clearance allows for a wide variety of treatment approaches including noncoplanar; ✓ Beam energy – 4, 6, 10, 15, 18, and 25 MV photon; 6, 9, 12, 15, 18, and 25 MeV; ✓ Collimation – Beam Modulator, an integrated high-resolution, multi-leaf collimator designed for extracranial SRS; ✓ Dose delivery system – includes an integrated multi-leaf collimator; ✓ Field size – 16 cm × 21 cm; ✓ Imaging – 4D Adaptive™ IGRT technology; ✓ Patient positioning/localization – BodyFix® and HeadFix® immobilization accessories; ✓ Treatment Sessions – single and fractionated | No | Radiation therapy treatment of malignant neoplastic diseases | Spine, lung, liver, prostate, pancreas, head, neck
TomoTherapy® Hi-Art® | TomoTherapy Inc. | ✓ Accuracy – beam modulating technology that divides a single beam into “beamlets” to better conform to tumors; ✓ Beam delivery – 360 degree; ✓ Beam energy – 6 MV (photon); ✓ Collimation – 64 leaf MLC; ✓ Design – linac mounted to a CT scanner-like ring gantry; ✓ Field size – 40 cm × 1.6 meters maximum; ✓ Imaging – integrated, 3D daily CTrue™ imaging; ✓ Output – 850 cGy/min (photon)^*^; ✓ Patient positioning/localization – AlignRT® (consisting of 2 ceiling- mounted 3D camera units) registers real-time image data and subsequently updates couch coordinates. Complements CTrue™ imaging when tumor is deep-seated or can move internally w/o external evidence; ✓ Treatment Sessions – single and fractionated | No | To tumors or other targeted tissues | Lung, liver, prostate, head, neck
Trilogy™ | Varian Medical Systems | ✓ Accuracy – beam modulating technology that divides a single beam into “beamlets” to better conform to tumors; ✓ Beam delivery – choice of Intensity modulated radiosurgery (IM-RS) with multi-leaf collimation – for lesions >2.5 cm, irregular shaped and >3 lesions OR Cone-based SRS for lesions <2.5 cm, not irregular and 1–3 lesions; ✓ Beam energy – 6 MV (photon)/4–22 MeV (6 energies); ✓ Collimation – 120 leaf MLC and conical collimator; ✓ Design – external system gating interface, remote couch motion; ✓ Field size – 15 cm × 15 cm; ✓ Imaging – PortalVision MV imager, On-Board kV Imager (amorphous silicon detector-based radiographic, fluoro and cone-beam CT).; ✓ Output – 1,000 MU/min (photon and electron); ✓ Patient position/localization – optional optical imaging-based patient positioning (FrameArray, BodyArray, and SonArray); ✓ Respiratory Gating – Real-time Position Management™ (RPM) System; ✓ Treatment Sessions – single and fractionated | No | Lesions, tumors and conditions anywhere in the body | Whole body

* Data derived from548

AVM: Arteriovenous malformation

Bq: Becquerel

cGY/min: Centigray per minute

cm: Centimeter

CT/MR: Computed tomography/magnetic resonance

FDA: United States Food and Drug Administration

IGRT: Image guided radiation therapy

kV: Kilovolt

Linac: Linear accelerator

MEV: Million electron volt

MLC: Multi-leaf collimator

mm: Millimeter

MU/min: Monitor units per minute

MV: Megavolt

NR: Not reported

RS: Radiosurgery

RT: Radiotherapy

SRS: Stereotactic radiosurgery

SRT: Stereotactic radiotherapy