# Recommendations

Recommendations for Stereotactic Body Radiation Therapy Procedures

Procedure Specifications | Accessory QC | Images QC | Treatment Planning QC | Simulation and Treatment | Followup
✓ Treatment-delivery unit requires implementation of/adherence to QA program; ✓ Mechanical tolerance must assure actual isocenter is within +/− 2 mm of planned isocenter; ✓ Precision should be validated each treatment session by QA process; ✓ QA: test beam alignment, calculate dose per unit time, measure MLC movement, measure gantry radiation fluence map for intensity modulated) | ✓ Routinely monitor to assure proper function | ✓ Digital images thoroughly investigated and corrected for significant spatial distortions; ✓ Combining MRI with CT image fusion used to minimize geometrical distortions in MR images | ✓ Various testing methods used with equal validity; ✓ Maintain system log; ✓ Check functionality and accuracy of input devices; ✓ Assure functionality and accuracy of output devices; ✓ Assure integrity of planning system files; ✓ Verify transfer of MLC data and other parameters; ✓ Assure system integrity of anatomical modeling; ✓ Operational test before treating patients | ✓ Comfortable position for the patient to “hold still” during treatment; ✓ Respiratory motion accounting program; ✓ Minimize the volume of surrounding normal tissues exposed to high dose levels; ✓ Validate precision QC process with each treatment session and throughout the treatment process | ✓ Maintenance of appropriate records; ✓ Determine local control, survival, and normal tissue injury

Information derived from the American College of Radiology Practice Guideline 2006^547^

CT: Computed tomography

MLC: Multi-leaf collimator

MR: Magnetic resonance

MRI: Magnetic resonance imaging

QA: Quality assurance

QC: Quality control