# Personnel Qualifications

Personnel Qualifications for Stereotactic Body Radiation Therapy

| Radiation Oncologist | Medical Physicists | Radiation Therapist
Qualifications | ✓ Certified in radiology, radiation oncology, or therapeutic radiology OR; ✓ Satisfactory completion in an approved residency program; ✓ Specific training on extracranial SRS | ✓ Certified in therapeutic radiological physics or radiological physics; ✓ Should be in accordance with the ACR Practice Guideline for Continuing Medical Education; ✓ Specific training in SRS should be obtained prior to performing any SBRT procedures | ✓ Fulfill state licensing requirements; ✓ Certified in radiation therapy
Responsibilities | ✓ Manage overall disease-specific treatment regimen; ✓ Recommend most ideal patient-positioning method; ✓ Recommend procedure to account for inherent organ motion; ✓ Supervise patient simulation; contour the outline of the gross tumor volume (GTV) on the treatment planning computer; ✓ Coordinate design for proper planning target volume (PTV); ✓ Convey case-specific expectations for prescribing radiation dose and setting limits on dose to adjacent normal tissues; ✓ Attend and direct actual treatment process; ✓ Follow patient with attention to disease control; ✓ Monitoring and treating potential complications | ✓ Acceptance testing and commissioning of SBRT system; ✓ Implementing and managing a QC program; ✓ Establishing a comprehensive QC checklist; ✓ Directly supervising or checking the 3D and/or intensity-modulated treatment planning process; ✓ Consulting with radiation oncologist to discuss optimal patient plan; ✓ Determine and check appropriate beam-delivery parameters (calculation of radiation beam parameters consistent with beam geometry); ✓ Double-checking beam delivery process to assure accurate fulfillment of prescription | ✓ Preparing treatment room; ✓ Assisting the treatment team with positioning/immobilization; ✓ Operating treatment unit after radiation oncologist & medical physicists approved clinical technical aspects for beam delivery

Information derived from the American College of Radiology Practice Guideline 2006^547^

SBRT: Stereotactic body radiotherapy

SRS: Stereotactic radiosurgery

QC: Quality control