# Excluded Studies

Full Article Excluded Studies

Reference | Exclusion Reason
(2001)125 | Not relevant
(2002)126 | Not a clinical study
(2002)127 | Not relevant
(2003)128 | Not a clinical study
Abbas et al. (2007)129 | Not a clinical study
Aboulafia et al. (2007)130 | Not relevant
Ahn et al. (2000)131 | Not relevant
Anantham et al. (2007)132 | Not relevant
Andrews (2007)133 | Not a clinical study
Andrews et al. (2006)134 | Not a clinical study
Arimura et al. (2009)135 | Treatment planning
Armstrong (2001)136 | Not a clinical study
Asamura (2006)137 | Not a clinical study
Astrahan (2008)138 | Not a clinical study
Attia et al. (2005)139 | Not a clinical study
Auberger et al. (2007)140 | Not relevant
Baisden et al. (2006)141 | Treatment planning
Bale and Sweeney (2002)142 | Not a clinical study
Ball and Withers (2007)143 | Not a clinical study
Ball D (2008)144 | Not a clinical study
Bance and Guha (2001)145 | Not a clinical study
Banki et al. (2009)146 | Not a clinical study
Barnett et al. (2000)147 | Not a clinical study
Baser et al. (2000)148 | Not relevant
Bauman et al. (2006)149 | Not relevant
Bayouth et al. (2007)150 | Not a clinical study
Benedict et al. (2008)151 | Not a clinical study
Bernier et al. (2006)152 | Not relevant
Bese et al. (2006)153 | Not a clinical study
Bhatnagar et al. (2002)154 | Not relevant
Bhatnagar et al. (2009)155 | Not relevant
Bissonnette et al. (2009)156 | Treatment planning
Blute ML (2009)157 | Not a clinical study
Bogart (2004)158 | Not a clinical study
Bogart (2006)159 | Not a clinical study
Bogart (2007)160 | Not a clinical study
Bourland and Shaw (2003)161 | Not a clinical study
Bradley (2007)162 | Not a clinical study
Brenner and Schwade (2007)163 | Not a clinical study
Bridgewater and Spittle (2000)164 | Not relevant
Brock (2007)165 | Not a clinical study
Brock et al. (2008)166 | Not a clinical study
Buatti et al. (2000)167 | Not a clinical study
Buatti et al. (2000)168 | Not relevant
Burton et al. (2002)169 | Not relevant
Buyyounouski et al. (2010)170 | Not a clinical study
Cadman (2007)171 | Treatment planning
Calcerrada Diaz-Santos et al. (2008)172 | Not a clinical study
Casamassima et al. (2006)173 | Treatment delivery
Cesaretti et al. (2008)174 | Not a clinical study
Chang and Adler (2001)175 | Not a clinical study
Chang and Adler (2001)176 | Not a clinical study
Chang and Lo (2003)177 | Not relevant
Chang and Roth (2007)178 | Not a clinical study
Chang and Saif (2008)179 | Editorial
Chang and Timmerman (2007)180 | Not a clinical study
Chang et al. (2007)181 | Not a clinical study
Chang et al. (2007)182 | Not a clinical study
Chang et al. (2008)183 | Not a clinical study
Chang et al. (2009)184 | Treatment planning
Chen et al. (2007)185 | Not a clinical study
Cheung et al. (2007)186 | Treatment planning
Chi et al. (2009)187 | Not a clinical study
Chin et al. (2001)188 | Not relevant
Cho et al. (2008)189 | Not relevant
Chou et al. (2001)190 | Not a clinical study
Christie et al. (2008)191 | Not a clinical study
Classen et al. (2003)192 | Not relevant
Clifford et al. (2009)193 | Not relevant
Coker (2003)194 | Not a clinical study
Collins et al. (2007)195 | Duplicate population
Colombo et al. (2006)196 | Not a clinical study
Crane and Willett (2009)197 | Editorial
Curtis and Teh (2006)198 | Not relevant
Dahele et al. (2008)199 | Treatment planning
Dawood (2008)200 | Not a clinical study
Day (2002)201 | Not a clinical study
De Mey et al. (2005)202 | Treatment delivery
De Pooter et al. (2007)203 | Treatment planning
Decker et al. (2006)204 | Not a clinical study
Demarco et al. (2002)205 | Not relevant
Derweesh and Novick (2003)206 | Not a clinical study
Dilling and Hoffe (2008)207 | Not a clinical study
Ding et al. (2005)208 | Not a clinical study
Dinka et al. (2005)209 | Not a clinical study
Dunlap et al. (2009)21 | No full article
Dunlap et al. (2010)210 | Duplicate population
Dvorak et al. (2005)211 | Not a clinical study
Ebert et al. (2001)212 | Treatment planning
Edler (2007)213 | Not relevant
El Hamri et al. (2005)214 | Not a clinical study
El-Sherif et al. (2005)215 | Not a clinical study
Ewing et al. (2010)216 | Treatment planning
Fatigante et al. (2005)217 | Not relevant
Fenwick et al. (2006)218 | Not a clinical study
FitzGerald et al. (2006)219 | Not relevant
Flickinger et al. (2003)220 | Not a clinical study
Flickinger et al. (2007)221 | Not a clinical study
Foote et al. (2004)222 | Not relevant
Fowler JF (2009)223 | Treatment planning
Friedman and Foote (2000)224 | Not a clinical study
Fritz et al. (2006)225 | Treatment delivery
Fuller DB (2009)226 | Editorial
Fuller et al. (2006)227 | Treatment delivery
Fuss (2001)228 | Not a clinical study
Fuss and Thomas (2004)229 | Not a clinical study
Fuss et al. (2006)230 | Treatment planning
Fuss et al. (2007)231 | Not a clinical study
Galvin and Bednarz (2008)232 | Quality Assurance
Ganslandt et al. (2003)233 | Not relevant
Ganz (2002)234 | Not a clinical study
Ganz (2007)235 | Not a clinical study
Gasent Blesa and Dawson (2008)236 | Not a clinical study
Gaspar (2007)237 | Not a clinical study
Gerber and Chan (2008)238 | Not a clinical study
Gerrard and Franks (2004)239 | Not relevant
Gerszten et al. (2006)240 | Not relevant
Gibbons et al. (2003)241 | Not relevant
Gibbs (2006)242 | Not a clinical study
Gibbs and Chang (2003)243 | Not a clinical study
Gottlieb (2001)244 | Not relevant
Gottlieb (2001)245 | Not a clinical study
Grills et al. (2007)246 | Treatment planning
Gross and Engenhart-Cabillic (2002)247 | Not a clinical study
Gross et al. (2003)248 | Treatment delivery
Grutters et al. (2010)249 | Not a clinical study
Guckenberger et al. (2006)250 | Treatment planning
Guckenberger et al. (2007)251 | Treatment delivery
Guckenberger et al. (2009)252 | Treatment planning
Guckenberger et al. (2009)253 | Treatment planning
Guckenberger et al. (2010)254 | Treatment planning
Guerrero and Li (2004)255 | Treatment planning
Hadinger et al. (2002)256 | Treatment planning
Haedinger et al. (2005)257 | Treatment planning
Hansen et al. (2006)258 | Treatment delivery
Hara et al. (2007)259 | Not a clinical study
Heinzerling et al. (2008)260 | Treatment delivery
Herbert et al. (2003)261 | Treatment delivery
Hermann et al. (2004)262 | Not a clinical study
Heron et al. (2003)263 | Not a clinical study
Heron et al. (2009)264 | Not relevant
Heros (2005)265 | Not a clinical study
Hevezi (2003)266 | Not a clinical study
Hevezi et al. (2010)267 | Not a clinical study
Hinson et al. (2007)268 | Treatment delivery
Hiraoka et al. (2007)269 | Not a clinical study
Hocht et al. (2005)270 | Treatment planning
Hogle (2006)271 | Not a clinical study
Hoh et al. (2007)272 | Not a clinical study
Holland (2001)273 | Not a clinical study
Holmes et al. (2008)274 | Not a clinical study
Hoogeman et al. (2008)275 | Treatment delivery
Hoogeman et al. (2009)276 | Treatment delivery
Horstmann et al. (2000)277 | Not relevant
Hui et al. (2004)278 | Not relevant
Huntzinger et al. (2007)279 | Not a clinical study
Imura et al. (2005)280 | Treatment delivery
Imura et al. (2008)281 | Treatment delivery
Inoue et al. (2010)282 | Not relevant
Isaksson et al. (2005)283 | Not relevant
Jaffray et al. (2007)284 | Not a clinical study
Jamal et al. (2008)285 | Not a clinical study
Jawahar et al. (2004)286 | Not relevant
Jeremic et al. (2000)287 | Not relevant
Jin et al. (2005)288 | Treatment planning
Jin et al. (2009)289 | Treatment planning
Joensuu et al. (2000)290 | Not a clinical study
Jozsef et al. (2000)291 | Treatment planning
Kassaee et al. (2003)292 | Treatment delivery
Katz et al. (2007)293 | Duplicate population
Kavanagh and Timmerman (2006)294 | Not a clinical study
Kavanagh et al. (2003)295 | Not a clinical study
Kavanagh et al. (2006)296 | Duplicate population
Kavanagh et al. (2007)297 | Not a clinical study
Kavanagh et al. (2007)298 | Not a clinical study
Kavanagh et al. (2008)299 | Not a clinical study
Kawaguchi et al. (2004)300 | Less than 3 patients
Kelly (2000)301 | Not a clinical study
Kenai et al. (2005)302 | Treatment planning
King et al. (2003)303 | Treatment delivery
King et al. (2008)304 | Duplicate population
King et al. (2009)305 | Duplicate population
King et al. (2009)306 | Editorial
Kitamura et al. (2002)307 | Not relevant
Kitamura et al. (2002)308 | Not relevant
Kitamura et al. (2003)309 | Treatment delivery
Koga et al. (2009)310 | Not relevant
Kommu et al. (2006)311 | Not relevant
Kondziolka et al. (2000)312 | Not a clinical study
Kondziolka et al. (2004)313 | Not a clinical study
Kondziolka et al. (2005)314 | Not a clinical study
Kondziolka et al. (2007)315 | Not a clinical study
Kontrisova et al. (2006)316 | Treatment planning
Koong et al. (2004)317 | Duplicate population
Koong et al. (2005)318 | Duplicate population
Kopek et al. (2010)319 | Duplicate population
Korreman et al. (2006)320 | Treatment planning
Kresl (2006)321 | Not a clinical study
Kunieda et al. (2004)322 | Treatment planning
Kunieda et al. (2008)323 | Treatment delivery
Kunzler et al. (2007)324 | Treatment delivery
Kupferman and Hanna (2008)325 | Not a clinical study
Laigle-Donadey et al. (2005)326 | Not relevant
Langner et al. (2009^327^ | Treatment delivery
Larre et al. (2007)328 | Not relevant
Lartigau et al. (2009)329 | Not a clinical study
Lawson et al. (2009)330 | Treatment planning
Lax et al. (2006)331 | Treatment planning
Leavitt et al. (2001)332 | Treatment delivery
Lee et al. (2000)333 | Treatment planning
Lee WR (2009)334 | Not a clinical study
Leskell (2007)335 | Not a clinical study
Li and Ma (2005)336 | Treatment planning
Liao et al. (2000)337 | Treatment planning
Lillard (2008)338 | Not a clinical study
Lind et al. (2001)339 | Not relevant
Lindquist and Paddick (2007)340 | Not relevant
Lindvall et al. (2008)341 | Not relevant
Linskey and Johnstone (2003)342 | Not a clinical study
Linthout et al. (2009)343 | Treatment delivery
Liu et al. (2004)344 | Treatment planning
Livi et al. (2005)345 | Not relevant
Lo et al. (2008)346 | Not a clinical study
Lo et al. (2009)347 | Not a clinical study
Lomax et al. (2003)348 | Treatment planning
Lu et al. (2008)349 | Treatment planning
Ma et al. (2003)350 | Not relevant
Maarouf et al. (2005)351 | Not relevant
Macdermed et al. (2008)352 | Not a clinical study
Martin and Gaya (2010)353 | Not a clinical study
Matsumoto et al. (2007)354 | Not relevant
McDermott et al. (2006)355 | Not relevant
McGarry et al. (2005)356 | Duplicate population
Meeks et al. (2003)357 | Treatment delivery
Mell and Mundt (2005)358 | Not relevant
Meretoja et al. (2008)359 | Not relevant
Mery et al. (2007)360 | Not a clinical study
Meyer et al. (2007)361 | Not a clinical study
Meyer et al. (2007)362 | Treatment planning
Mignano et al. (2001)363 | Treatment planning
Minn et al. (2009)364 | Treatment planning
Molla et al. (2005)365 | Duplicate population
Morgia and De (2009)366 | Editorial
Muacevic et al. (2003)367 | Not relevant
Muacevic et al. (2004)368 | Not a clinical study
Muller et al. (2004)369 | Treatment delivery
Murphy (2004)370 | Not a clinical study
Murphy et al. (2002)371 | Treatment delivery
Murphy et al. (2003)372 | Treatment delivery
Murphy MJ (2009)373 | Treatment planning
Murray et al. (2007)374 | Treatment delivery
Naff (2007)375 | Not relevant
Nagata et al. (2007)376 | Not a clinical study
Nakagawa et al. (2003)377 | Treatment planning
Nakaji and Spetzler (2004)378 | Not relevant
Nakamura et al. (2001)379 | Treatment planning
Nedzi LA (2008)380 | Not a clinical study
Nguyen et al. (2008)381 | Not a clinical study
Nieder et al. (2009)382 | Not a clinical study
Niranjan and Lunsford (2000)383 | Not a clinical study
Niranjan et al. (2003)384 | Not a clinical study
Niranjan et al. (2007)385 | Not a clinical study
Niranjan et al. (2007)386 | Not a clinical study
No Authors Listed (2003)387 | Not relevant
No authors listed (2006)388 | Not a clinical study
No Authors Listed (2007)389 | Not relevant
No Authors Listed (2007)390 | Not relevant
Noda et al. (2009)391 | Not relevant
Okunieff et al. (2006)392 | Duplicate population
Onishi et al. (2003)393 | Treatment delivery
Orecchia (2007)394 | Not a clinical study
Pan et al. (2007)395 | Treatment delivery
Pang (2003)396 | Not a clinical study
Papiez and Timmerman (2008)397 | Not a clinical study
Papiez et al. (2003)398 | Not a clinical study
Park et al. (2008)399 | Treatment planning
Parman (2004)400 | Not a clinical study
Pass H (2008)401 | Not a clinical study
Pawlicki et al. (2007)402 | Not a clinical study
Pennathur et al. (2007)403 | Duplicate population
Petersch et al. (2004)404 | Treatment delivery
Petrovich and Yu (2003)405 | Not relevant
Pishvaian et al. (2006)406 | Treatment delivery
Polina et al. (2010)407 | Not a clinical study
Poll et al. (2008)408 | Not a clinical study
Pollock (2006)409 | Not a clinical study
Pott et al. (2005)410 | Not relevant
Potters et al. (2005)411 | Not a clinical study
Prabhu and Demonte (2003)412 | Not relevant
Prevost et al. (2008)413 | Treatment delivery
Prevost et al. (2008)414 | Treatment planning
Purdie et al. (2006)415 | Treatment delivery
Quang et al. (2007)416 | Not a clinical study
Quinn (2002)417 | Not a clinical study
Rassiah-Szegedi et al. (2006)418 | Treatment planning
Ratto et al. (2000)419 | Not relevant
Regine (2003)420 | Not a clinical study
Regis et al. (2009)421 | Not relevant
Riboldi et al. (2006)422 | Treatment planning
Rock et al. (2004)423 | Not a clinical study
Rockhill (2007)424 | Not a clinical study
Romanelli et al. (2003)425 | Not a clinical study
Romanelli et al. (2006)426 | Not a clinical study
Romanelli et al. (2006)427 | Not relevant
Rosahl et al. (2002)428 | Not a clinical study
Rosenzweig et al. (2003)429 | Not a clinical study
Rosenzweig et al. (2009)430 | Not a clinical study
Rousseau and Gibon (2000)431 | Not a clinical study
Rutten and Deneufbourg (2000)432 | Not relevant
Ryken et al. (2001)433 | Treatment delivery
Samper et al. (2006)434 | Not relevant
Sankaranarayanan et al. (2003)435 | Treatment planning
Sarfaraz et al. (2007)436 | Not a clinical study
Sasai et al. (2000)437 | Treatment planning
Saunders (2007)438 | Not a clinical study
Savides (2006)439 | Not a clinical study
Saw et al. (2008)440 | Not a clinical study
Sawrie et al. (2010)441 | Not a clinical study
Schefter et al. (2005)442 | Duplicate population
Scheib et al. (2004)443 | Not relevant
Schellenberg et al. (2010)444 | Duplicate population
Schlaefer et al. (2005)445 | Treatment planning
Schweikard et al. (2000)446 | Treatment delivery
Schweikard et al. (2004)447 | Treatment delivery
Scorsetti and Bignardi (2008)448 | Not a clinical study
Seki et al. (2007)449 | Treatment planning
Senan et al. (2007)450 | Not a clinical study
Seppenwoolde et al. (2002)451 | Treatment delivery
Sharma et al. (2010)452 | Not relevant
Shepard et al. (2000)453 | Treatment planning
Sherwood and Brock (2007)454 | Not a clinical study
Shibuya and Tsujii (2005)455 | Not relevant
Shirato et al. (2003)456 | Not relevant
Shirato et al. (2006)457 | Not a clinical study
Shirato et al. (2007)458 | Not a clinical study
Shiu et al. (2003)459 | Treatment delivery
Shoshan et al. (2005)460 | Not a clinical study
Shrieve et al. (2004)461 | Not a clinical study
Siddiqui et al. (2009)462 | Not relevant
Silvano (2006)463 | Not a clinical study
Singletary (2001)464 | Not relevant
Siva et al. (2010)465 | Not a clinical study
Slotman et al. (2005)466 | Not relevant
Slotman et al. (2006)467 | Not a clinical study
Smink and Schneider et al. (2008)468 | Not a clinical study
Smit (2000)469 | Not a clinical study
Smith and Chuang (2007)470 | Not a clinical study
Snell et al. (2006)471 | Treatment planning
Soete et al. (2006)472 | Treatment planning
Solberg et al. (2001)473 | Treatment planning
Solberg et al. (2004)474 | Not relevant
Solberg et al. (2008)475 | Quality Assurance
Solberg et al. (2008)476 | Not a clinical study
Song et al.(no year)477 | Not a clinical study
Sonke et al. (2009)478 | Treatment delivery
Sotiropoulou et al. (2009)479 | Not relevant
Spadea et al. (2008)480 | Treatment delivery
St. George et al. (2002)481 | Not relevant
Stancanello et al. (2005)482 | Treatment planning
Steinke (2006)483 | Not relevant
Sterzing et al. (2007)484 | Not relevant
Sterzing et al. (2008)485 | Not relevant
Storme et al. (2006)486 | Not a clinical study
Strassmann et al. (2004)487 | Treatment planning
Strassmann et al. (2006)488 | Treatment delivery
Suzuki et al. (2007)489 | Treatment delivery
Taguchi et al. (2007)490 | Treatment delivery
Takayama et al. (2005)491 | Treatment planning
Takeda et al. (2005)492 | Treatment planning
Takeda et al. (2008)493 | Duplicate population
Takeda et al. (2009)494 | Treatment planning
Takeuchi et al. (2003)495 | Treatment delivery
Teh et al. (2007)496 | Not a clinical study
Theil and Winfield (2008)497 | Not a clinical study
Theodorou et al. (2000)498 | Treatment planning
Theodorou et al. (no year)499 | Not a clinical study
Thieke et al. (2006)500 | Treatment planning
Timmerman et al. (2003)501 | Duplicate population
Timmerman et al. (2003)502 | Not a clinical study
Timmerman et al. (2006)503 | Not a clinical study
Timmerman et al. (2007)504 | Not a clinical study
Timmerman et al. (2007)505 | Treatment planning
Timmerman et al. (2007)506 | Not a clinical study
Timmerman et al. (2007)507 | Not a clinical study
Timmerman et al. (2009)508 | Not a clinical study
Tobler et al. (2004)509 | Treatment planning
Tonn (2004)510 | Not a clinical study
Tsai et al. (2001)511 | Treatment planning
Uematsu et al. (2000)512 | No relevant outcomes
Underberg et al. (2005)513 | Treatment delivery
Underberg et al. (2006)514 | Treatment delivery
Vaidya et al. (2002)515 | Not relevant
Van Houtte (2003)516 | Not a clinical study
Van Der Voort Van Zyp et al. (2010)517 | Duplicate population
Varga et al. (2009)518 | Not a clinical study
Vassiliev et al. (2009)519 | Treatment planning
Verbakel et al. (2009)520 | Treatment delivery
Verellen et al. (2006)521 | Treatment planning
Videtic et al. (2010)522 | Duplicate population
Voynov et al. (2006)523 | Not relevant
Vricella et al. (2009)524 | Not a clinical study
Wagner et al. (2003)525 | Treatment planning
Wagner et al. (2007)526 | Not a clinical study
Wakelee et al. (2008)527 | Not a clinical study
Wakisaka et al. (2000)528 | Treatment planning
Wallen (2006)529 | Not a clinical study
Wiegner and King (2010)530 | No full article
Willoughby et al. (2006)531 | Not relevant
Wilt et al. (2008)532 | Not relevant
Wu et al. (2003)533 | Treatment planning
Wu et al. (2008)534 | Treatment delivery
Wu et al. (2009)535 | Treatment planning
Wulf et al. (2004)536 | Duplicate population
Wunderink et al. (2007)537 | Treatment planning
Wurm et al. (2006)538 | Not relevant
Xiao et al. (2009)539 | Treatment delivery
Yaeger T.E. (2009)540 | Editorial
Yin et al. (2004)541 | Treatment delivery
Yin et al. (2008)542 | Treatment delivery
Yousefi et al. (2007)543 | Treatment delivery
Yu and Shepard (2003)544 | Not a clinical study
Zamzuri et al. (2006)545 | Not relevant
Zimmermann et al. (2010)546 | Not a clinical study