# Included Studies

Studies Included To Address Guiding Question 3

Reference
Chang et al. (2009)1
Ahn et al. (2009)2
Aluwini et al. (2010)3
Aoki et al. (2007)4
Baumann et al. (2006)5
Baumann et al. (2008)6
Beitler et al. (2004)7
Bolzicco et al. (2010)8
Bradley et al. (2010)9
Brown et al. (2007)10
Cardenes et al. (2010)11
Casamassima et al. (2008)12
Chang et al. (2008)13
Chawla et al. (2009)14
Choi et al. (2008)15
Choi et al. (2009)16
Collins et al. (2009)17
Coon et al. (2008)18
Crabtree et al. (2010)19
Dawson et al. (2006)20
Dunlap et al. (2010)21
Ernst-Stecken et al. (2006)22
Freeman et al. (2011)23
Fritz et al. (2008)24
Fuller et al. (2008)25
Gerszten et al. (2003)26
Goodman et al. (2010)27
Grills et al. (2010)28
Guckenberger et al. (2007)29
Guckenberger et al. (2009)30
Guckenberger et al. (2010)31
Gunven et al. (2003)32
Haasbeek et al. (2009)33
Hamamoto et al. (2010)34
Harada et al. (2002)35
Henderson et al. (2008)36
Hodge et al. (2006)37
Hof et al. (2007)38
Hof et al. (2007)39
Hof et al. (2009)40
Hoopes et al. (2007)41
Hoyer et al. (2005)42
Hoyer et al. (2006)43
Ishimori et al. (2004)44
Jereczek-Fossa et al. (2008)45
Jorcano et al. (2010)46
Joyner et al. (2006)47
Kang et al. (2010)48
Katoh et al. (2008)49
Kawase et al. (2009)50
Kim et al. (2008)51
Kim et al. (2009)52
Kim et al. (2010)53
Kopek et al. (2009)54
Kopek et al. (2010)55
Koto et al. (2007)56
Kunos et al. (2008)57
Lagerwaard et al. (2008)58
Le et al. (2006)59
Lee et al. (2003)60
Lee et al. (2009)61
Louis et al. (2010)62
Madsen et al. (2007)63
Mahadevan et al. (2010)64
McCammon et al. (2009)65
Milano et al. (2009)66
Milano et al. (2009)67
Milano et al. (2009)68
Muacevic et al. (2007)69
Nakagawa et al. (2000)70
Norihisa et al. (2008)71
Nuyttens et al. (2006)72
Nuyttens et al. (2007)73
Oermann et al. (2010)74
Olsen et al. (2009)75
Onimaru et al. (2008)76
Onishi et al. (2004)77
Paludan et al. (2006)78
Pennathur et al. (2009)79
Polistina et al. (2010)80
Ponsky et al. (2007)81
Ricardi et al. (2007)82
Ricardi et al. (2009)83
Romero et al. (2006)84
Rusthoven et al. (2009)85
Rusthoven et al. (2009)86
Rusthoven et al. (2009)87
Salazar et al. (2008)88
Schellenberg et al. (2008)89
Scorsetti et al. (2007)90
Seo et al. (2010)91
Seong et al. (2009)92
Shin et al. (2010)93
Shioyama et al. (2005)94
Sinha et al. (2006)95
Son et al. (2010)96
Song et al. (2005)97
Song et al. (2009)98
Stephans et al. (2009)99
Stephans et al. (2009)100
Stintzing et al. (2010)101
Stintzing et al. (2010)102
Svedman et al. (2006)103
Svedman et al. (2008)104
Takeda et al. (2009)105
Takeda et al. (2010)106
Teh et al. (2007)107
Timmerman et al. (2006)108
Timmerman et al. (2010)109
Townsend et al. (2010)110
Trovo et al. (2010)111
Tse et al. (2008)112
Uematsu et al. (2001)113
Unger et al. (2010)114
Vahdat et al. (2010)115
Van der Voort van Zyp et al. (2009)116
Whyte et al. (2003)117
Wulf et al. (2001)118
Wulf et al. (2006)119
Xia et al. (2006)120
Yamashita et al. (2010)121
Yang et al. (2010)122
Yoon et al. (2006)123
Zimmermann et al. (2006)124