# References Cited in Appendixes

1 Chang DT, Schellenberg D, Shen J, et al. Stereotactic radiotherapy for unresectable adenocarcinoma of the pancreas. Cancer. 02. 1. 2009;115(3):665-72. [pmid: 19117351].
2 Ahn SH, Han MS, Yoon JH, et al. Treatment of stage I non-small cell lung cancer with CyberKnife, image-guided robotic stereotactic radiosurgery. Oncol Rep. 03. 2009;21(3):693-6. [pmid: 19212628].
3 Aluwini S, van RP, Hoogeman M, et al. CyberKnife stereotactic radiotherapy as monotherapy for low- to intermediate-stage prostate cancer: early experience, feasibility, and tolerance. J Endourol. 05. 2010;24(5):865-9. [pmid: 20433370].
4 Aoki M, Abe Y, Kondo H, et al. Clinical outcome of stereotactic body radiotherapy of 54 Gy in nine fractions for patients with localized lung tumor using a custom-made immobilization system. Radiat Med. 07. 2007;25(6):289-94. [pmid: 17634882].
5 Baumann P, Nyman J, Lax I, et al. Factors important for efficacy of stereotactic body radiotherapy of medically inoperable stage I lung cancer. A retrospective analysis of patients treated in the Nordic countries. Acta Oncol. 2006;45(7):787-95. [pmid: 16982541].
6 Baumann P, Nyman J, Hoyer M, et al. Stereotactic body radiotherapy for medically inoperable patients with stage I non-small cell lung cancer - a first report of toxicity related to COPD/CVD in a non-randomized prospective phase II study. Radiother Oncol. 09. 2008;88(3):359-67. [pmid: 18768228].
7 Beitler JJ, Makara D, Silverman P, et al. Definitive, high-dose-per-fraction, conformal, stereotactic external radiation for renal cell carcinoma. Am J Clin Oncol. 12. 2004;27(6):646-8. [pmid: 15577450].
8 Bolzicco G, Favretto MS, Scremin E, et al. Image-guided stereotactic body radiation therapy for clinically localized prostate cancer: preliminary clinical results. Technol Cancer Res Treat. 10. 2010;9(5):473-7. [pmid: 20815418].
9 Bradley JD, El Naqa I, Drzymala RE, et al. Stereotactic body radiation therapy for early-stage non-small-cell lung cancer: the pattern of failure is distant. Int J Radiat Oncol Biol Phys. 07. 15. 2010;77(4):1146-50. [pmid: 19800181].
10 Brown WT, Wu X, Wen BC, et al. Early results of CyberKnife image-guided robotic stereotactic radiosurgery for treatment of lung tumors. Comput Aided Surg. 09. 2007;12(5):253-61. [pmid: 17957532].
11 Cardenes HR, Price TR, Perkins SM, et al. Phase I feasibility trial of stereotactic body radiation therapy for primary hepatocellular carcinoma. Clin Transl Oncol. 03. 2010;12(3):218-25. [pmid: 20231127].
12 Casamassima F, Masi L, Bonucci I, et al. Relevance of biologically equivalent dose values in outcome evaluation of stereotactic radiotherapy for lung nodules. Int J Radiat Oncol Biol Phys. 05. 1. 2008;71(1):145-51. [pmid: 18164855].
13 Chang JY, Balter PA, Dong L, et al. Stereotactic body radiation therapy in centrally and superiorly located stage I or isolated recurrent non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 11. 15. 2008;72(4):967-71. [pmid: 18954709].
14 Chawla S, Chen Y, Katz AW, et al. Stereotactic body radiotherapy for treatment of adrenal metastases. Int J Radiat Oncol Biol Phys. 09. 1. 2009;75(1):71-5. [pmid: 19250766].
15 Choi BO, Choi IB, Jang HS, et al. Stereotactic body radiation therapy with or without transarterial chemoembolization for patients with primary hepatocellular carcinoma: preliminary analysis. BMC Cancer. 11. 27. 2008;8:351. [pmid: 19038025].
16 Choi CW, Cho CK, Yoo SY, et al. Image-guided stereotactic body radiation therapy in patients with isolated para-aortic lymph node metastases from uterine cervical and corpus cancer. Int J Radiat Oncol Biol Phys. 05. 1. 2009;74(1):147-53. [pmid: 18990511].
17 Collins BT, Vahdat S, Erickson K, et al. Radical cyberknife radiosurgery with tumor tracking: an effective treatment for inoperable small peripheral stage I non-small cell lung cancer. J Hematol Oncol. 2009;2:1. [pmid: 19149899].
18 Coon D, Gokhale AS, Burton SA, et al. Fractionated stereotactic body radiation therapy in the treatment of primary, recurrent, and metastatic lung tumors: the role of positron emission tomography/computed tomography-based treatment planning. Clin Lung Cancer. 07. 2008;9(4):217-21. [pmid: 18650169].
19 Crabtree TD, Denlinger CE, Meyers BF, et al. Stereotactic body radiation therapy versus surgical resection for stage I non-small cell lung cancer. J Thorac Cardiovasc Surg. 08. 2010;140(2):377-86. [pmid: 20400121].
20 Dawson LA, Eccles C, Craig T. Individualized image guided iso-NTCP based liver cancer SBRT. Acta Oncol. 2006;45(7):856-64. [pmid: 16982550].
21 Dunlap NE, Cai J, Biedermann GB, et al. Chest wall volume receiving >30 Gy predicts risk of severe pain and/or rib fracture after lung stereotactic body radiotherapy. Int J Radiat Oncol Biol Phys. 03. 1. 2010;76(3):796-801. Epub 2009 May 8. [pmid: 19427740].
22 Ernst-Stecken A, Lambrecht U, Mueller R, et al. Hypofractionated stereotactic radiotherapy for primary and secondary intrapulmonary tumors: first results of a phase I/II study. Strahlenther Onkol. 12. 2006;182(12):696-702. [pmid: 17149575].
23 Freeman DE, King CR. Stereotactic body radiotherapy for low-risk prostate cancer: five-year outcomes. Radiat Oncol. 01. 10. 2011;6(1):3. [pmid: 21219625].
24 Fritz P, Kraus HJ, Blaschke T, et al. Stereotactic, high single-dose irradiation of stage I non-small cell lung cancer (NSCLC) using four-dimensional CT scans for treatment planning. Lung Cancer. 05. 2008;60(2):193-9. [pmid: 18045732].
25 Fuller DB, Naitoh J, Lee C, et al. Virtual HDR CyberKnife treatment for localized prostatic carcinoma: dosimetry comparison with HDR brachytherapy and preliminary clinical observations. Int J Radiat Oncol Biol Phys. 04. 1. 2008;70(5):1588-97. [pmid: 18374232].
26 Gerszten PC, Ozhasoglu C, Burton SA, et al. CyberKnife frameless single-fraction stereotactic radiosurgery for tumors of the sacrum. Neurosurg Focus. 08. 15. 2003;15(2):E7. [pmid: 15350038].
27 Goodman KA, Wiegner EA, Maturen KE, et al. Dose-escalation study of single-fraction stereotactic body radiotherapy for liver malignancies. Int J Radiat Oncol Biol Phys. 10. 1. 2010;78(2):486-93. [pmid: 20350791].
28 Grills IS, Mangona VS, Welsh R, et al. Outcomes after stereotactic lung radiotherapy or wedge resection for stage I non-small-cell lung cancer. J Clin Oncol. 02. 20. 2010;28(6):928-35. [pmid: 20065181].
29 Guckenberger M, Heilman K, Wulf J, et al. Pulmonary injury and tumor response after stereotactic body radiotherapy (SBRT): results of a serial follow-up CT study. Radiother Oncol. 12. 2007;85(3):435-42. [pmid: 18053602].
30 Guckenberger M, Wulf J, Mueller G, et al. Dose-response relationship for image-guided stereotactic body radiotherapy of pulmonary tumors: relevance of 4D dose calculation. Int J Radiat Oncol Biol Phys. 05. 1. 2009;74(1):47-54. [pmid: 18977095].
31 Guckenberger M, Bachmann J, Wulf J, et al. Stereotactic body radiotherapy for local boost irradiation in unfavourable locally recurrent gynaecological cancer. Radiother Oncol. 01. 2010;94(1):53-9. [pmid: 20079550].
32 Gunven P, Blomgren H, Lax I. Radiosurgery for recurring liver metastases after hepatectomy. Hepatogastroenterology. 09. 2003;50(53):1201-4. [pmid: 14571698].
33 Haasbeek CJ, Lagerwaard FJ, de Jaeger K, et al. Outcomes of stereotactic radiotherapy for a new clinical stage I lung cancer arising postpneumonectomy. Cancer. 02. 1. 2009;115(3):587-94. [pmid: 19130457].
34 Hamamoto Y, Kataoka M, Yamashita M, et al. Local control of metastatic lung tumors treated with SBRT of 48 Gy in four fractions: in comparison with primary lung cancer. Jpn J Clin Oncol. 02. 2010;40(2):125-9. [pmid: 19825814].
35 Harada T, Shirato H, Ogura S, et al. Real-time tumor-tracking radiation therapy for lung carcinoma by the aid of insertion of a gold marker using bronchofiberscopy. Cancer. 10. 15. 2002;95(8):1720-7. [pmid: 12365020].
36 Henderson M, McGarry R, Yiannoutsos C, et al. Baseline pulmonary function as a predictor for survival and decline in pulmonary function over time in patients undergoing stereotactic body radiotherapy for the treatment of stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 10. 1. 2008;72(2):404-9. [pmid: 18394819].
37 Hodge W, Tome WA, Jaradat HA, et al. Feasibility report of image guided stereotactic body radiotherapy (IG-SBRT) with tomotherapy for early stage medically inoperable lung cancer using extreme hypofractionation. Acta Oncol. 2006;45(7):890-6. [pmid: 16982555].
38 Hof H, Hoess A, Oetzel D, et al. Stereotactic single-dose radiotherapy of lung metastases. Strahlenther Onkol. 12. 2007;183(12):673-8. [pmid: 18040611].
39 Hof H, Muenter M, Oetzel D, et al. Stereotactic single-dose radiotherapy (radiosurgery) of early stage nonsmall-cell lung cancer (NSCLC). Cancer. 07. 1. 2007;110(1):148-55. [pmid: 17516437].
40 Hof H, Zgoda J, Nill S, et al. Time- and dose-dependency of radiographic normal tissue changes of the lung after stereotactic radiotherapy. Int J Radiat Oncol Biol Phys. 08. 1. 2010;77(5):1369-74. Epub 2009 Nov 24. [pmid: 19932943].
41 Hoopes DJ, Tann M, Fletcher JW, et al. FDG-PET and stereotactic body radiotherapy (SBRT) for stage I non-small-cell lung cancer. Lung Cancer. 05. 2007;56(2):229-34. [pmid: 17353064].
42 Hoyer M, Roed H, Sengelov L, et al. Phase-II study on stereotactic radiotherapy of locally advanced pancreatic carcinoma. Radiother Oncol. 07. 2005;76(1):48-53. [pmid: 15990186].
43 Hoyer M, Roed H, Traberg HA, et al. Phase II study on stereotactic body radiotherapy of colorectal metastases. Acta Oncol. 2006;45(7):823-30. [pmid: 16982546].
44 Ishimori T, Saga T, Nagata Y, et al. 18F-FDG and 11C-methionine PET for evaluation of treatment response of lung cancer after stereotactic radiotherapy. Ann Nucl Med. 12. 2004;18(8):669-74. [pmid: 15682847].
45 Jereczek-Fossa BA, Kowalczyk A, D’Onofrio A, et al. Three-dimensional conformal or stereotactic reirradiation of recurrent, metastatic or new primary tumors. Analysis of 108 patients. Strahlenther Onkol. 01. 2008;184(1):36-40. [pmid: 18188521].
46 Jorcano S, Molla M, Escude L, et al. Hypofractionated extracranial stereotactic radiotherapy boost for gynecologic tumors: a promising alternative to high-dose rate brachytherapy. Technol Cancer Res Treat. 10. 2010;9(5):509-14. [pmid: 20815422].
47 Joyner M, Salter BJ, Papanikolaou N, et al. Stereotactic body radiation therapy for centrally located lung lesions. Acta Oncol. 2006;45(7):802-7. [pmid: 16982543].
48 Kang JK, Kim MS, Kim JH, et al. Oligometastases confined one organ from colorectal cancer treated by SBRT. Clin Exp Metastasis. 04. 2010;27(4):273-8. [pmid: 20373133].
49 Katoh N, Onimaru R, Sakuhara Y, et al. Real-time tumor-tracking radiotherapy for adrenal tumors. Radiother Oncol. 06. 2008;87(3):418-24. [pmid: 18439693].
50 Kawase T, Takeda A, Kunieda E, et al. Extrapulmonary soft-tissue fibrosis resulting from hypofractionated stereotactic body radiotherapy for pulmonary nodular lesions. Int J Radiat Oncol Biol Phys. 06. 1. 2009;74(2):349-54. [pmid: 19427551].
51 Kim MS, Choi C, Yoo S, et al. Stereotactic body radiation therapy in patients with pelvic recurrence from rectal carcinoma. Jpn J Clin Oncol. 10. 2008;38(10):695-700. [pmid: 18723850].
52 Kim MS, Yoo SY, Cho CK, et al. Stereotactic body radiation therapy using three fractions for isolated lung recurrence from colorectal cancer. Oncology. 2009;76(3):212-9. [pmid: 19218825].
53 Kim JH, Kim MS, Yoo SY, et al. Stereotactic body radiotherapy for refractory cervical lymph node recurrence of nonanaplastic thyroid cancer. Otolaryngol Head Neck Surg. 03. 2010;142(3):338-43. [pmid: 20172377].
54 Kopek N, Paludan M, Petersen J, et al. Co-morbidity index predicts for mortality after stereotactic body radiotherapy for medically inoperable early-stage non-small cell lung cancer. Radiother Oncol. 12. 2009;93(1):122-4. Epub 2009 Jun 22. [pmid: 19552979].
55 Kopek N, Holt MI, Hansen AT, et al. Stereotactic body radiotherapy for unresectable cholangiocarcinoma. Radiother Oncol. 01. 2010;94(1):47-52. [pmid: 19963295].
56 Koto M, Takai Y, Ogawa Y, et al. A phase II study on stereotactic body radiotherapy for stage I non-small cell lung cancer. Radiother Oncol. 12. 2007;85(3):429-34. [pmid: 18022720].
57 Kunos C, von Gruenigen V, Waggoner S, et al. Cyberknife radiosurgery for squamous cell carcinoma of vulva after prior pelvic radiation therapy. Technol Cancer Res Treat. 10. 2008;7(5):375-80. [pmid: 18783287].
58 Lagerwaard FJ, Haasbeek CJ, Smit EF, et al. Outcomes of risk-adapted fractionated stereotactic radiotherapy for stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 03. 1. 2008;70(3):685-92. [pmid: 18164849].
59 Le QT, Loo BW, Ho A, et al. Results of a phase I dose-escalation study using single-fraction stereotactic radiotherapy for lung tumors. J Thorac Oncol. 10. 2006;1(8):802-9. [pmid: 17409963].
60 Lee SW, Choi EK, Park HJ, et al. Stereotactic body frame based fractionated radiosurgery on consecutive days for primary or metastatic tumors in the lung. Lung Cancer. 06. 2003;40(3):309-15. [pmid: 12781430].
61 Lee MT, Kim JJ, Dinniwell R, et al. Phase I study of individualized stereotactic body radiotherapy of liver metastases. J Clin Oncol. 04. 1. 2009;27(10):1585-91. [pmid: 19255313].
62 Louis C, Dewas S, Mirabel X, et al. Stereotactic radiotherapy of hepatocellular carcinoma: preliminary results. Technol Cancer Res Treat. 10. 2010;9(5):479-87. [pmid: 20815419].
63 Madsen BL, Hsi RA, Pham HT, et al. Stereotactic hypofractionated accurate radiotherapy of the prostate (SHARP), 33.5 Gy in five fractions for localized disease: first clinical trial results. Int J Radiat Oncol Biol Phys. 03. 15. 2007;67(4):1099-105. [pmid: 17336216].
64 Mahadevan A, Jain S, Goldstein M, et al. Stereotactic body radiotherapy and gemcitabine for locally advanced pancreatic cancer. Int J Radiat Oncol Biol Phys. 11. 1. 2010;78(3):735-42. Epub 2010 Feb 18. [pmid: 20171803].
65 McCammon R, Schefter TE, Gaspar LE, et al. Observation of a dose-control relationship for lung and liver tumors after stereotactic body radiation therapy. Int J Radiat Oncol Biol Phys. 01. 1. 2009;73(1):112-8. [pmid: 18786780].
66 Milano MT, Chen Y, Katz AW, et al. Central thoracic lesions treated with hypofractionated stereotactic body radiotherapy. Radiother Oncol. 06. 2009;91(3):301-6. [pmid: 19329210].
67 Milano MT, Philip A, Okunieff P. Analysis of patients with oligometastases undergoing two or more curative-intent stereotactic radiotherapy courses. Int J Radiat Oncol Biol Phys. 03. 1. 2009;73(3):832-7. [pmid: 18760543].
68 Milano MT, Katz AW, Okunieff P. Patterns of recurrence after curative-intent radiation for oligometastases confined to one organ. Am J Clin Oncol. 04. 2010;33(2):157-63. Epub 2009 Sep 18. [pmid: 19770627].
69 Muacevic A, Drexler C, Wowra B, et al. Technical description, phantom accuracy, and clinical feasibility for single-session lung radiosurgery using robotic image-guided real-time respiratory tumor tracking. Technol Cancer Res Treat. 08. 2007;6(4):321-8. [pmid: 17668940].
70 Nakagawa K, Aoki Y, Tago M, et al. Megavoltage CT-assisted stereotactic radiosurgery for thoracic tumors: original research in the treatment of thoracic neoplasms. Int J Radiat Oncol Biol Phys. 09. 1. 2000;48(2):449-57. [pmid: 10974461].
71 Norihisa Y, Nagata Y, Takayama K, et al. Stereotactic body radiotherapy for oligometastatic lung tumors. Int J Radiat Oncol Biol Phys. 10. 1. 2008;72(2):398-403. [pmid: 18374506].
72 Nuyttens JJ, Prevost JB, Praag J, et al. Lung tumor tracking during stereotactic radiotherapy treatment with the CyberKnife: marker placement and early results. Acta Oncol. 2006;45(7):961-5. [pmid: 16982564].
73 Nuyttens JJ, Prevost JB, Van der Voort van Zijp NC, et al. Curative stereotactic robotic radiotherapy treatment for extracranial, extrapulmonary, extrahepatic, and extraspinal tumors: technique, early results, and toxicity. Technol Cancer Res Treat. 12. 2007;6(6):605-10. [pmid: 17994790].
74 Oermann EK, Slack RS, Hanscom HN, et al. A pilot study of intensity modulated radiation therapy with hypofractionated stereotactic body radiation therapy (SBRT) boost in the treatment of intermediate- to high-risk prostate cancer. Technol Cancer Res Treat. 10. 2010;9(5):453-62. [pmid: 20815416].
75 Olsen CC, Welsh J, Kavanagh BD, et al. Microscopic and macroscopic tumor and parenchymal effects of liver stereotactic body radiotherapy. Int J Radiat Oncol Biol Phys. 04. 1. 2009;73(5):1414-24. [pmid: 18990508].
76 Onimaru R, Fujino M, Yamazaki K, et al. Steep dose-response relationship for stage I non-small-cell lung cancer using hypofractionated high-dose irradiation by real-time tumor-tracking radiotherapy. Int J Radiat Oncol Biol Phys. 02. 1. 2008;70(2):374-81. [pmid: 18029106].
77 Onishi H, Kuriyama K, Komiyama T, et al. Clinical outcomes of stereotactic radiotherapy for stage I non-small cell lung cancer using a novel irradiation technique: patient self-controlled breath-hold and beam switching using a combination of linear accelerator and CT scanner. Lung Cancer. 07. 2004;45(1):45-55. [pmid: 15196734].
78 Paludan M, Traberg HA, Petersen J, et al. Aggravation of dyspnea in stage I non-small cell lung cancer patients following stereotactic body radiotherapy: Is there a dose-volume dependency. Acta Oncol. 2006;45(7):818-22. [pmid: 16982545].
79 Pennathur A, Luketich JD, Heron DE, et al. Stereotactic radiosurgery for the treatment of stage I non-small cell lung cancer in high-risk patients. J Thorac Cardiovasc Surg. 03. 2009;137(3):597-604. [pmid: 19258073].
80 Polistina F, Costantin G, Casamassima F, et al. Unresectable locally advanced pancreatic cancer: a multimodal treatment using neoadjuvant chemoradiotherapy (gemcitabine plus stereotactic radiosurgery) and subsequent surgical exploration. Ann Surg Oncol. 08. 2010;17(8):2092-101. Epub 2010 Mar 12. [pmid: 20224860].
81 Ponsky LE, Mahadevan A, Gill IS, et al. Renal radiosurgery: initial clinical experience with histological evaluation. Surg Innov. 12. 2007;14(4):265-9. [pmid: 18178914].
82 Ricardi U, Guarneri A, Mantovani C, et al. Stereotactic body radiation therapy for early non-small cell lung cancer: experience at the University of Turin. J Thorac Oncol. 05. 2007;2(5 Suppl):S47. [pmid: 17457235].
83 Ricardi U, Filippi AR, Guarneri A, et al. Dosimetric predictors of radiation-induced lung injury in stereotactic body radiation therapy. Acta Oncol. 2009;48(4):571-7. [pmid: 19031164].
84 Mendez RA, Wunderink W, Hussain SM, et al. Stereotactic body radiation therapy for primary and metastatic liver tumors: A single institution phase i-ii study. Acta Oncol. 2006;45(7):831-7. [pmid: 16982547].
85 Rusthoven KE, Hammerman SF, Kavanagh BD, et al. Is there a role for consolidative stereotactic body radiation therapy following first-line systemic therapy for metastatic lung cancer? A patterns-of-failure analysis. Acta Oncol. 2009;48(4):578-83. [pmid: 19373699].
86 Rusthoven KE, Kavanagh BD, Cardenes H, et al. Multi-institutional phase I/II trial of stereotactic body radiation therapy for liver metastases. J Clin Oncol. 04. 1. 2009;27(10):1572-8. [pmid: 19255321].
87 Rusthoven KE, Kavanagh BD, Burri SH, et al. Multi-institutional phase I/II trial of stereotactic body radiation therapy for lung metastases. J Clin Oncol. 04. 1. 2009;27(10):1579-84. [pmid: 19255320].
88 Salazar OM, Sandhu TS, Lattin PB, et al. Once-weekly, high-dose stereotactic body radiotherapy for lung cancer: 6-year analysis of 60 early-stage, 42 locally advanced, and 7 metastatic lung cancers, Int J Radiat Oncol Biol Phys. 11. 1. 2008;72(3):707-15. [pmid: 18455322].
89 Schellenberg D, Goodman KA, Lee F, et al. Gemcitabine chemotherapy and single-fraction stereotactic body radiotherapy for locally advanced pancreatic cancer. Int J Radiat Oncol Biol Phys. 11. 1. 2008;72(3):678-86. [pmid: 18395362].
90 Scorsetti M Navarria P Facoetti A Effectiveness of stereotactic body radiotherapy in the treatment of inoperable early-stage lung cancer Anticancer Res 2007 0927(5B3615 9 17972525
91 Seo YS, Kim MS, Yoo SY, et al. Preliminary result of stereotactic body radiotherapy as a local salvage treatment for inoperable hepatocellular carcinoma. J Surg Oncol. 09. 1. 2010;102(3):209-14. [pmid: 20740576].
92 Seong J, Lee IJ, Shim SJ, et al. A multicenter retrospective cohort study of practice patterns and clinical outcome on radiotherapy for hepatocellular carcinoma in Korea. Liver Int. 2009;29(2):147-52. [pmid: 18795897].
93 Shin YJ, Kim MS, Yoo SY, et al. Pilot study of stereotactic body radiotherapy forhuge hepatocellular carcinoma unsuitable for other therapies. Tumori. 01. 2010;96(1):65-70. [pmid: 20437860].
94 Shioyama Y, Nakamura K, Anai S, et al. Stereotactic radiotherapy for lung and liver tumors using a body cast system setup accuracy and preliminary clinical outcome. Radiat Med. 09. 2005;23(6):407-13. [pmid: 16389982].
95 Sinha B, McGarry RC. Stereotactic body radiotherapy for bilateral primary lung cancers: the Indiana University experience. Int J Radiat Oncol Biol Phys. 11. 15. 2006;66(4):1120-4. [pmid: 17145532].
96 Son SH, Choi BO, Ryu MR, et al. Stereotactic body radiotherapy for patients with unresectable primary hepatocellular carcinoma: dose-volumetric parameters predicting the hepatic complication. Int J Radiat Oncol Biol Phys. 11. 15. 2010;78(4):1073-80. Epub 2010 Mar 6. [pmid: 20207492].
97 Song DY, Benedict SH, Cardinale RM, et al. Stereotactic body radiation therapy of lung tumors: preliminary experience using normal tissue complication probability-based dose limits. Am J Clin Oncol. 12. 2005;28(6):591-6. [pmid: 16317270].
98 Song SY, Choi W, Shin SS, et al. Fractionated stereotactic body radiation therapy for medically inoperable stage I lung cancer adjacent to central large bronchus. Lung Cancer. 10. 2009;66(1):89-93. [pmid: 19168260].
99 Stephans KL, Djemil T, Reddy CA, et al. Comprehensive analysis of pulmonary function test (PFT) changes after stereotactic body radiotherapy (SBRT) for stage I lung cancer in medically inoperable patients. J Thorac Oncol. 07. 2009;4(7):838-44. [pmid: 19487961].
100 Stephans KL, Djemil T, Reddy CA, et al. A comparison of two stereotactic body radiation fractionation schedules for medically inoperable stage I non-small cell lung cancer: the Cleveland Clinic experience. J Thorac Oncol. 08. 2009;4(8):976-82. [pmid: 19633473].
101 Stintzing S, Hoffmann RT, Heinemann V, et al. Frameless single-session robotic radiosurgery of liver metastases in colorectal cancer patients. Eur J Cancer. 04. 2010;46(6):1026-32. [pmid: 20153959].
102 Stintzing S, Hoffmann RT, Heinemann V, et al. Radiosurgery of liver tumors: value of robotic radiosurgical device to treat liver tumors. Ann Surg Oncol. 11. 2010;17(11):2877-83. [pmid: 20574773].
103 Svedman C, Sandstrom P, Pisa P, et al. A prospective Phase II trial of using extracranial stereotactic radiotherapy in primary and metastatic renal cell carcinoma. Acta Oncol. 2006;45(7):870-5. [pmid: 16982552].
104 Svedman C, Karlsson K, Rutkowska E, et al. Stereotactic body radiotherapy of primary and metastatic renal lesions for patients with only one functioning kidney. Acta Oncol. 2008;47(8):1578-83. [pmid: 18607859].
105 Takeda A, Sanuki N, Kunieda E, et al. Stereotactic body radiotherapy for primary lung cancer at a dose of 50 Gy total in five fractions to the periphery of the planning target volume calculated using a superposition algorithm. Int J Radiat Oncol Biol Phys. 02. 1. 2009;73(2):442-8. [pmid: 18990507].
106 Takeda A, Ohashi T, Kunieda E, et al. Early graphical appearance of radiation pneumonitis correlates with the severity of radiation pneumonitis after stereotactic body radiotherapy (SBRT) in patients with lung tumors. Int J Radiat Oncol Biol Phys. 07. 1. 2010;77(3):685-90. [pmid: 20510193].
107 Teh BS, Paulino AC, Lu HH, et al. Versatility of the Novalis system to deliver image-guided stereotactic body radiation therapy (SBRT) for various anatomical sites. Technol Cancer Res Treat. 08. 2007;6(4):347-54. [pmid: 17668943].
108 Timmerman R, McGarry R, Yiannoutsos C, et al. Excessive toxicity when treating central tumors in a phase II study of stereotactic body radiation therapy for medically inoperable early-stage lung cancer. J Clin Oncol. 10. 20. 2006;24(30):4833-9. [pmid: 17050868].
109 Timmerman R, Paulus R, Galvin J, et al. Stereotactic body radiation therapy for inoperable early stage lung cancer. JAMA. 03. 17. 2010;303(11):1070-6. [pmid: 20233825].
110 Townsend NC, Huth BJ, Ding W, et al. Acute toxicity after CyberKnife-delivered hypofractionated radiotherapy for treatment of prostate cancer. Am J Clin Oncol. 02. 2011;34(1):6-10. Epub 2010 Jan 8. [pmid: 20065849].
111 Trovo M, Linda A, El NI, et al. Early and late lung radiographic injury following stereotactic body radiation therapy (SBRT). Lung Cancer. 07. 2010;69(1):77-85. [pmid: 19910075].
112 Tse RV, Hawkins M, Lockwood G, et al. Phase I study of individualized stereotactic body radiotherapy for hepatocellular carcinoma and intrahepatic cholangiocarcinoma. J Clin Oncol. 02. 1. 2008;26(4):657-64. [pmid: 18172187].
113 Uematsu M, Shioda A, Suda A, et al. Computed tomography-guided frameless stereotactic radiotherapy for stage I non-small cell lung cancer: a 5-year experience. Int J Radiat Oncol Biol Phys. 11. 1. 2001;51(3):666-70. [pmid: 11597807].
114 Unger K, Ju A, Oermann E, et al. CyberKnife for hilar lung tumors: report of clinical response and toxicity. J Hematol Oncol. 2010;3:39. [pmid: 20969774].
115 Vahdat S, Oermann EK, Collins SP, et al. CyberKnife radiosurgery for inoperable stage IA non-small cell lung cancer: 18F-fluorodeoxyglucose positron emission tomography/computed tomography serial tumor response assessment. J Hematol Oncol. 2010;3:6. [pmid: 20132557].
116 van der Voort van Zyp NC, Prevost JB, Hoogeman MS, et al. Stereotactic radiotherapy with real-time tumor tracking for non-small cell lung cancer: Clinical outcome. Radiother Oncol. 06. 2009;91(3):296-300. [pmid: 19297048].
117 Whyte RI, Crownover R, Murphy MJ, et al. Stereotactic radiosurgery for lung tumors: preliminary report of a phase I trial. Ann Thorac Surg. 04. 2003;75(4):1097-101. [pmid: 12683544].
118 Wulf J, Hadinger U, Oppitz U, et al. Stereotactic radiotherapy of targets in the lung and liver. Strahlenther Onkol. 12. 2001;177(12):645-55. [pmid: 11789403].
119 Wulf J, Guckenberger M, Haedinger U, et al. Stereotactic radiotherapy of primary liver cancer and hepatic metastases. Acta Oncol. 2006;45(7):838-47. [pmid: 16982548].
120 Xia T, Li H, Sun Q, et al. Promising clinical outcome of stereotactic body radiation therapy for patients with inoperable Stage I/II non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 09. 1. 2006;66(1):117-25. [pmid: 16765528].
121 Yamashita H, Kobayashi-Shibata S, Terahara A, et al. Prescreening based on the presence of CT-scan abnormalities and biomarkers (KL-6 and SP-D) may reduce severe radiation pneumonitis after stereotactic radiotherapy. Radiat Oncol. 2010;5:32. [pmid: 20459699].
122 Yang ZX, Wang D, Wang G, et al. Clinical study of recombinant adenovirus-p53 combined with fractionated stereotactic radiotherapy for hepatocellular carcinoma. J Cancer Res Clin Oncol. 04. 2010;136(4):625-30. [pmid: 19882171].
123 Yoon SM, Choi EK, Lee SW, et al. Clinical results of stereotactic body frame based fractionated radiation therapy for primary or metastatic thoracic tumors. Acta Oncol. 2006;45(8):1108-14. [pmid: 17118847].
124 Zimmermann FB, Geinitz H, Schill S, et al. Stereotactic hypofractionated radiotherapy in stage I T1–2 N0 M0) non-small-cell lung cancer (NSCLC). Acta Oncol. 2006;45(7):796-801. [pmid: 16982542].
125 Cyberknife image-guided radiosurgery system successful. Expert Rev Anticancer Ther. 08. 2001;1(2):166.
126 Images from Headache. Tumor-related headache as a late complication of radiosurgery. Headache. 09. 2002;42(8):834. [pmid: 12390652].
127 Minimally invasive procedure and robotic technology combined to treat prostate cancer. Expert Rev Anticancer Ther. 10. 2002;2(5):482.
128 Radiation therapy. A valuable treatment tool. Mayo Clin Health Lett. 06. 2003;21(6):1-3.
129 Abbas G, Schuchert MJ, Pennathur A, et al. Ablative treatments for lung tumors: radiofrequency ablation, stereotactic radiosurgery, and microwave ablation. Thorac Surg Clin. 05. 2007;17(2):261-71. [pmid: 17626404].
130 Aboulafia AJ, Levine AM, Schmidt D, et al. Surgical therapy of bone metastases. Semin Oncol. 06. 2007;34(3):206-14. [pmid: 17560982].
131 Ahn YC, Lee KC, Kim DY, et al. Fractionated stereotactic radiation therapy for extracranial head and neck tumors. Int J Radiat Oncol Biol Phys. 09. 1. 2000;48(2):501-5. [pmid: 10974468].
132 Anantham D, Feller-Kopman D, Shanmugham LN, et al. Electromagnetic navigation bronchoscopy-guided fiducial placement for robotic stereotactic radiosurgery of lung tumors: a feasibility study. Chest. 09. 2007;132(3):930-5. [pmid: 17646225].
133 Andrews DW. Chained lightning: Part III - Emerging technology, novel therapeutic strategies, and new energy modalities for radiosurgery - Commentary. Neurosurgery. 12. 2007;61(6):1129.
134 Andrews DW, Bednarz G, Evans JJ, et al. A review of 3 current radiosurgery systems. Surg Neurol. 12. 2006;66(6):559-64. [pmid: 17145309].
135 Arimura H, Egashira Y, Shioyama Y, et al. Computerized method for estimation of the location of a lung tumor on EPID cine images without implanted markers in stereotactic body radiotherapy. Phys Med Biol. 02. 7. 2009;54(3):665-77. [pmid: 19131668].
136 Armstrong J. Advances in radiation technology can improve survival and quality of life for cancer patients. Ir J Med Sci. 01. 2001;170(1):63-8. [pmid: 11440417].
137 Asamura H. Treatment of choice for stage I non-small cell lung cancer: surgery or radiotherapy. J Thorac Oncol. 10. 2006;1(8):766-7. [pmid: 17409957].
138 Astrahan M. BED calculations for fractions of very high dose: in regard to Park et al. (Int J Radiat Oncol Biol Phys 2007;69:S623-S624). Int J Radiat Oncol Biol Phys. 07. 1. 2008;71(3):963. [pmid: 18514798].
139 Attia M, Menhel J, Alezra D, et al. Radiosurgery--LINAC or gamma knife: 20 years of controversy revisited. Isr Med Assoc J. 09. 2005;7(9):583-8. [pmid: 16190483].
140 Auberger T, Seydl K, Futschek T, et al. Photons or protons: precision radiotherapy of lung cancer. Strahlenther Onkol. 12. 2007;183(Spec No 2):3-6. [pmid: 18166995].
141 Baisden JM, Reish AG, Sheng K, et al. Dose as a function of liver volume and planning target volume in helical tomotherapy, intensity-modulated radiation therapy-based stereotactic body radiation therapy for hepatic metastasis. Int J Radiat Oncol Biol Phys. 10. 1. 2006;66(2):620-5. [pmid: 16904845].
142 Bale RJ, Sweeney RA. In regard to Salter et al., IJROBP 2001;51:555–562. Int J Radiat Oncol Biol Phys. 05. 1. 2002;53(1):253-4. [pmid: 12007968].
143 Ball D, Withers HR. Stereotactic radiotherapy for stage I non-small-cell lung cancer--the triumph of technology over biology. Nat Clin Pract Oncol. 11. 2007;4(11):614-5. [pmid: 17848932].
144 Ball D. Extracranial stereotactic body radiotherapy for stage I non-small cell lung cancer: still investigational or standard of care. J Thorac Oncol. 11. 2008;3(11):1209-10. [pmid: 18978553].
145 Bance M, Guha A. Radiation-induced malignant tumors after stereotactic radiosurgery. Otol Neurotol. 01. 2001;22(1):124-5. [pmid: 11314707].
146 Banki F, Luketich JD, Chen H, et al. Stereotactic radiosurgery for lung cancer. Minerva Chir. 12. 2009;64(6):589-98. [pmid: 20029356].
147 Barnett GH, Suh JH, Crownover RL. Recent advances in the treatment of skull base tumors using radiation. Neurosurg Clin North Am. 10. 2000;11(4):587-96. [pmid: 11082169].
148 Baser ME, Evans DG, Jackler RK, et al. Neurofibromatosis 2, radiosurgery and malignant nervous system tumours. Br J Cancer. 02. 2000;82(4):998. [pmid: 10732777].
149 Bauman G, Wong E, McDermott M. Fractionated radiotherapy techniques. Neurosurg Clin North Am. 04. 2006;17(2):99-110. [pmid: 16793502].
150 Bayouth JE, Kaiser HS, Smith MC, et al. Image-guided stereotactic radiosurgery using a specially designed high-dose-rate linac. Med Dosim. 2007;32(2):134-41. [pmid: 17472892].
151 Benedict SH, Bova FJ, Clark B, et al. Anniversary Paper: the role of medical physicists in developing stereotactic radiosurgery. Med Phys. 09. 2008;35(9):4262-77. [pmid: 18841876].
152 Bernier J, Viale G, Orecchia R, et al. Partial irradiation of the breast: Old challenges, new solutions. Breast. 08. 2006;15(4):466-75. [pmid: 16439129].
153 Bese NS, Kiel K, El-Gueddari B, et al. Radiotherapy for breast cancer in countries with limited resources: program implementation and evidence-based recommendations. Breast J. 01. 2006;12(Suppl 1):S96-102. [pmid: 16430403].
154 Bhatnagar A, Heron DE, Kondziolka D, et al. Analysis of repeat stereotactic radiosurgery for progressive primary and metastatic CNS tumors. Int J Radiat Oncol Biol Phys. 07. 1. 2002;53(3):527-32. [pmid: 12062593].
155 Bhatnagar JP, Novotny J, Niranjan A, et al. First year experience with newly developed Leksell Gamma Knife Perfexion. J Med Phys. 07. 2009;34(3):141-8. [pmid: 20098561].
156 Bissonnette JP, Purdie TG, Higgins JA, et al. Cone-beam computed tomographic image guidance for lung cancer radiation therapy. Int J Radiat Oncol Biol Phys. 03. 1. 2009;73(3):927-34. [pmid: 19095368].
157 Blute ML. No proof of inferiority: open radical retropubic prostatectomy remains state-of-the-art surgical technique for localized prostate cancer. J Urol. 06. 2009;181(6):2421-3. [pmid: 19371882].
158 Bogart JA. Hypofractionated radiotherapy for advanced non-small-cell lung cancer: is the LINAC half full. J Clin Oncol. 03. 1. 2004;22(5):765-8. [pmid: 14990629].
159 Bogart JA. Definitive radiotherapy for stage I non-small cell lung cancer: ain’t nothing like the real thing. J Thorac Oncol. 10. 2006;1(8):763-5. [pmid: 17409956].
160 Bogart JA. Stereotactic body radiotherapy for poor-risk lung cancer: “more cyber, less knife?”. Cancer J. 03. 2007;13(2):75-7. [pmid: 17476132].
161 Bourland JD, Shaw EG. The evolving role of biological imaging in stereotactic radiosurgery. Technol Cancer Res Treat. 04. 2003;2(2):135-9. [pmid: 12680794].
162 Bradley J. Radiographic response and clinical toxicity following SBRT for stage I lung cancer. J Thorac Oncol. 07. 2007;2(7 Suppl 3):S118-S124. [pmid: 17603307].
163 Brenner MJ, Schwade J. Response to letter: colonic apple-core lesion resulting from cyberknife treatment of unresectable pancreatic cancer. Pancreas. 01. 2007;34(1):167-8. [pmid: 17198203].
164 Bridgewater CH, Spittle MF. The future of radiotherapy and chemotherapy in head and neck cancer. J Laryngol Otol. 06. 2000;114(6):411-3. [pmid: 10962670].
165 Brock KK. Image registration in intensity- modulated, image-guided and stereotactic body radiation therapy. Front Radiat Ther Oncol. 2007;40:94-115. [pmid: 17641504].
166 Brock J, Ashley S, Bedford J, et al. Review of hypofractionated small volume radiotherapy for early-stage non-small cell lung cancer. Clin Oncol (R Coll Radiol). 11. 2008;20(9):666-76. [pmid: 18676130].
167 Buatti JM, Meeks SL, Friedman WA, et al. Stereotactic radiosurgery: techniques and clinical applications. Surg Oncol Clin N Am. 07. 2000;9(3):469-87. [pmid: 10853137].
168 Buatti JM, Friedman WA, Meeks SL, et al. RTOG 90–05 the real conclusion. Int J Radiat Oncol Biol Phys. 05. 1. 2000;47(2):269-71. [pmid: 10802348].
169 Burton KE, Thomas SJ, Whitney D, et al. Accuracy of a relocatable stereotactic radiotherapy head frame evaluated by use of a depth helmet. Clin Oncol (R Coll Radiol). 02. 2002;14(1):31-9. [pmid: 11898783].
170 Buyyounouski MK, Price RA Jr, Harris EE, et al. Stereotactic body radiotherapy for primary management of early-stage, low- to intermediate-risk prostate cancer: report of the American Society for Therapeutic Radiology and Oncology Emerging Technology Committee. Int J Radiat Oncol Biol Phys. 04. 2010;76(5):1297-304. [pmid: 20338473].
171 Cadman P. An investigation of beam parameters for Co-60 tomotherapy. Med Phys. 10. 2007;34(10):3838-43. [pmid: 17985629].
172 Calcerrada Diaz-Santos N, Blasco Amaro JA, Cardiel GA, et al. The safety and efficacy of robotic image-guided radiosurgery system treatment for intra- and extracranial lesions: A systematic review of the literature. Radiother Oncol. 12. 2008;89(3):245-53. [pmid: 18760852].
173 Casamassima F, Cavedon C, Francescon P, et al. Use of motion tracking in stereotactic body radiotherapy: Evaluation of uncertainty in off-target dose distribution and optimization strategies. Acta Oncol. 2006;45(7):943-7. [pmid: 16982561].
174 Cesaretti JA, Pennathur A, Rosenstein BS, et al. Stereotactic radiosurgery for thoracic malignancies. Ann Thorac Surg. 02. 2008;85(2):S785-791. [pmid: 18222218].
175 Chang SD, Adler JR. Robotics and radiosurgery--the cyberknife. Stereotact Funct Neurosurg. 2001;76(3-4):204-8. [pmid: 12378098].
176 Chang SD, Adler JR Jr. Current status and optimal use of radiosurgery. Oncology (Huntingt). 02. 2001;15(2):209-16. [pmid: 11252934].
177 Chang EL, Lo S. Diagnosis and management of central nervous system metastases from breast cancer. Oncologist. 2003;8(5):398-410. [pmid: 14530493].
178 Chang JY, Roth JA. Stereotactic body radiation therapy for stage I non-small cell lung cancer. Thorac Surg Clin. 05. 2007;17(2):251-9. [pmid: 17626403].
179 Chang BW, Saif MW. Stereotactic body radiation therapy (SBRT) in pancreatic cancer: is it ready for prime time. JOP. 2008;9(6):676-82. [pmid: 18981547].
180 Chang BK, Timmerman RD. Stereotactic body radiation therapy: a comprehensive review. Am J Clin Oncol. 12. 2007;30(6):637-44. [pmid: 18091059].
181 Chang CY, Tu CH, Chiang TS, et al. Acute gastric ulcer associated with gamma knife treatment (conformal stereotactic radiotherapy) of recurrent hepatocellular carcinoma. Endoscopy. 02. 2007;39(Suppl 1):E154. [pmid: 16673314].
182 Chang ST, Goodman KA, Yang GP, et al. Stereotactic body radiotherapy for unresectable pancreatic cancer. Front Radiat Ther Oncol. 2007;40:386-94. [pmid: 17641521].
183 Chang JY, Dong L, Liu H, et al. Image-guided radiation therapy for non-small cell lung cancer. J Thorac Oncol. 02. 2008;3(2):177-86. [pmid: 18303441].
184 Chang J, Yenice KM, Jiang K, et al. Effect of MLC leaf width and PTV margin on the treatment planning of intensity-modulated stereotactic radiosurgery (IMSRS) or radiotherapy (IMSRT). Med Dosim. 2009;34(2):110-6. [pmid: 19410139].
185 Chen JC, Rahimian J, Girvigian MR, et al. Contemporary methods of radiosurgery treatment with the Novalis linear accelerator system. Neurosurg Focus. 2007;23(6):E4. [pmid: 18081481].
186 Cheung JY, Ng KP, Yu CP, et al. Comparative study of treatment dose plans after the refinement of Leksell Gamma Knife single-beam dose profiles. Med Phys. 09. 2007;34(9):3556-61. [pmid: 17926958].
187 Chi A, Liao Z, Nguyen NP, et al. Systemic review of the patterns of failure following stereotactic body radiation therapy in early-stage non-small-cell lung cancer: clinical implications. Radiother Oncol. 01. 2010;94(1):1-11. Epub 2010 Jan 13. [pmid: 20074823].
188 Chin LS, Ma L, DiBiase S. Radiation necrosis following gamma knife surgery: a case-controlled comparison of treatment parameters and long-term clinical follow up. J Neurosurg. 06. 2001;94(6):899-904. [pmid: 11409517].
189 Cho B, Suh Y, Dieterich S, et al. A monoscopic method for real-time tumour tracking using combined occasional x-ray imaging and continuous respiratory monitoring. Phys Med Biol. 06. 7. 2008;53(11):2837-55. [pmid: 18460750].
190 Chou RH, Wilder RB, Wong MS, et al. Recent advances in radiotherapy for head and neck cancers. Ear Nose Throat J. 10. 2001;80(10):704-7. 711. [pmid: 11605568].
191 Christie NA, Pennathur A, Burton SA, et al. Stereotactic radiosurgery for early stage non-small cell lung cancer: rationale, patient selection, results, and complications. Semin Thorac Cardiovasc Surg. 2008;20(4):290-7. [pmid: 19251167].
192 Classen J, Schmidberger H, Meisner C, et al. Radiotherapy for stages IIA/B testicular seminoma: final report of a prospective multicenter clinical trial. J Clin Oncol. 03. 15. 2003;21(6):1101-6. [pmid: 12637477].
193 Clifford W, Sharpe H, Khu KJ, et al. Gamma Knife patients’ experience: lessons learned from a qualitative study. J Neurooncol. 05. 2009;92(3):387-92. [pmid: 19357964].
194 Coker NJ. The radiosurgical option: too many unanswered questions. Arch Otolaryngol Head Neck Surg. 08. 2003;129(8):906-7. [pmid: 12925355].
195 Collins BT, Erickson K, Reichner CA, et al. Radical stereotactic radiosurgery with real-time tumor motion tracking in the treatment of small peripheral lung tumors. Radiat Oncol. 2007;2:39. [pmid: 17953752].
196 Colombo F, Francescon P, Cavedon C. Head frames to image guidance, a brief history of stereotactic radiosurgery. Nowotwory. 2006;56(3):235-41.
197 Crane CH, Willett CG. Stereotactic radiotherapy for pancreatic cancer. Cancer. 02. 1. 2009;115(3):468-72. [pmid: 19117338].
198 Doh L, Curtis AE, Teh BS. Renal-cell carcinoma. N Engl J Med. 03. 9. 2006;354(10):1095-6. [pmid: 16525153].
199 Dahele M, Pearson S, Purdie T, et al. Practical considerations arising from the implementation of lung stereotactic body radiation therapy (SBRT) at a comprehensive cancer center. J Thorac Oncol. 11. 2008;3(11):1332-41. [pmid: 18978570].
200 Dawood O. CyberKnife Treatment of Prostate Cancer: A Reply to Bentzen and Wasserman. Int J Radiat Oncol Biol Phys. 09. 1. 2008;72(1):14-8.
201 Day JD. Malignant schwannoma. J Neurosurg. 04. 2002;96(4):805-6. [pmid: 11990826].
202 De Mey J, Van De Steene J, Vandenbroucke F, et al. Percutaneous placement of marking coils before stereotactic radiation therapy of malignant lung lesions. J Vasc Interv Radiol. 01. 2005;16(1):51-6. [pmid: 15640410].
203 de Pooter JA, Wunderink W, Mendez RA, et al. PTV dose prescription strategies for SBRT of metastatic liver tumours. Radiother Oncol. 11. 2007;85(2):260-6. [pmid: 17905455].
204 Decker RH, Tanoue LT, Colasanto JM, et al. Evaluation and definitive management of medically inoperable early stage non-small-cell lung cancer. Part 2: newer treatment modalities. Oncology (Huntingt). 07. 2006;20(8):899-905. [pmid: 16922260].
205 Demarco JJ, Chetty IJ, Solberg TD. A Monte Carlo tutorial and the application for radiotherapy treatment planning. Med Dosim. 2002;27(1):43-50. [pmid: 12019965].
206 Derweesh IH, Novick AC. Small renal tumors: natural history, observation strategies and emerging modalities of energy based tumor ablation. Can J Urol. 06. 2003;10(3):1871-9. [pmid: 12892573].
207 Dilling TJ, Hoffe SE. Stereotactic body radiation therapy: transcending the conventional to improve outcomes. Cancer Control. 04. 2008;15(2):104-11. [pmid: 18376377].
208 Ding M, Newman F, Raben D. New radiation therapy techniques for the treatment of head and neck cancer. Otolaryngol Clin North Am. 04. 2005;38(2):371-95. [pmid: 15823599].
209 Dinka D, Nyce JM, Timpka T. GammaKnife surgery: safety and the identity of users. Technol Health Care. 2005;13(6):485-95. [pmid: 16340092].
210 Dunlap NE, Larner JM, Read PW, et al. Size matters: a comparison of T1 and T2 peripheral non-small-cell lung cancers treated with stereotactic body radiation therapy (SBRT). J Thorac Cardiovasc Surg. 09. 2010;140(3):583-9. Epub 2010 May 15. [pmid: 20478576].
211 Dvorak P, Georg D, Bogner J, et al. Impact of IMRT and leaf width on stereotactic body radiotherapy of liver and lung lesions. Int J Radiat Oncol Biol Phys. 04. 1. 2005;61(5):1572-81. [pmid: 15817364].
212 Ebert MA, Herbert CE, Spry NA, et al. System validation and work practice efficiency gains of a new localization method for stereotactic radiotherapy. Australas Radiol. 2001;45(2):182-8. [pmid: 11380361].
213 Edler A. Special anesthetic considerations for stereotactic radiosurgery in children. J Clin Anesth. 12. 2007;19(8):616-8. [pmid: 18083476].
214 El Hamri AK, Monk J, Plowman PN. Stereotactic radiosurgery at St. Bartholomew’s hospital: third quinquennial review. Br J Radiol. 05. 2005;78(929):384-93. [pmid: 15845929].
215 El-Sherif A, Luketich JD, Landreneau RJ, et al. New therapeutic approaches for early stage non-small cell lung cancer. Surg Oncol. 07. 2005;14(1):27-32. [pmid: 15777887].
216 Ewing MM, DesRosiers C, Fakiris AJ, et al. Conformality study for stereotactic radiosurgery of the lung. Med Dosim. 36(1):14-20. Epub 2010 Jan 27. [pmid: 20110162].
217 Fatigante L, Ducci F, Campoccia S, et al. Long-term results in patients affected by testicular seminoma treated with radiotherapy: risk of second malignancies. Tumori. 03. 2005;91(2):144-50. [pmid: 15948542].
218 Fenwick JD, Tome WA, Soisson ET, et al. Tomotherapy and other innovative IMRT delivery systems. Semin Radiat Oncol. 10. 2006;16(4):199-208. [pmid: 17010902].
219 FitzGerald TJ, Aronowitz J, Giulia CM, et al. The effect of radiation therapy on normal tissue function. Hematol Oncol Clin North Am. 02. 2006;20(1):141-63. [pmid: 16580561].
220 Flickinger JC, Kondziolka D, Lunsford LD. Radiobiological analysis of tissue responses following radiosurgery. Technol Cancer Res Treat. 04. 2003;2(2):87-92. [pmid: 12680788].
221 Flickinger JC, Kondziolka D, Niranjan A, et al. Dose selection in stereotactic radiosurgery. 2007:28-42.
222 Foote RL, Pollock BE, Link MJ, et al. Leksell Gamma Knife coordinate setting slippage: how often, how much. J Neurosurg. 10. 2004;101(4):590-3. [pmid: 15481711].
223 Fowler JF. Sensitivity analysis of parameters in linear-quadratic radiobiologic modeling. Int J Radiat Oncol Biol Phys. 04. 1. 2009;73(5):1532-7. [pmid: 19306749].
224 Friedman WA, Foote KD. Linear accelerator radiosurgery for skull base tumors. Neurosurg Clin North Am. 10. 2000;11(4):667-80. [pmid: 11082177].
225 Fritz P, Kraus HJ, Dolken W, et al. Technical note: gold marker implants and high-frequency jet ventilation for stereotactic, single-dose irradiation of liver tumors. Technol Cancer Res Treat. 02. 2006;5(1):9-14. [pmid: 16417397].
226 Fuller DB. Balancing on a knife’s edge: evidence-based medicine and the marketing of health technology. In regard to Bentzen et al. (Int J Radiat Oncol Biol Phys 2008; 72:12–14. Int J Radiat Oncol Biol Phys. 02. 1. 2009;73(2):637-8. [pmid: 19147029].
227 Fuller CD, Thomas CR, Schwartz S, et al. Method comparison of ultrasound and kilovoltage x-ray fiducial marker imaging for prostate radiotherapy targeting. Phys Med Biol. 10. 7. 2006;51(19):4981-93. [pmid: 16985282].
228 Fuss M. Analysis of dose distribution in multiple-target gamma knife radiosurgery. Int J Radiat Oncol Biol Phys. 03. 1. 2001;49(3):901-2. [pmid: 11265658].
229 Fuss M, Thomas CR Jr. Stereotactic body radiation therapy: an ablative treatment option for primary and secondary liver tumors. Ann Surg Oncol. 02. 2004;11(2):130-8. [pmid: 14761915].
230 Fuss M, Shi C, Papanikolaou N. Tomotherapeutic stereotactic body radiation therapy: Techniques and comparison between modalities. Acta Oncol. 2006;45(7):953-60. [pmid: 16982563].
231 Fuss M, Boda-Heggemann J, Papanikolau N, et al. Image-guidance for stereotactic body radiation therapy. Med Dosim. 2007;32(2):102-10. [pmid: 17472889].
232 Galvin JM, Bednarz G. Quality assurance procedures for stereotactic body radiation therapy. Int J Radiat Oncol Biol Phys. 05. 1. 2008;71(1 Suppl):S122-S125. [pmid: 18406909].
233 Ganslandt O, Mueller R, Mueller W, et al. Simple invasive fixation device for fractionated stereotactic LINAC based radiotherapy. Acta Neurochir. 04. 2003;145(4):289-94. [pmid: 12748889].
234 Ganz JC. Gamma knife radiosurgery and its possible relationship to malignancy: a review. J Neurosurg. 12. 2002;97(5 Suppl):644-52. [pmid: 12507113].
235 Ganz JC. Surgery or gamma knife. J Neurosurg. 05. 2007;106(5):937-8. [pmid: 17542547].
236 Gasent Blesa JM, Dawson LA. Options for radiotherapy in the treatment of liver metastases. Clin Transl Oncol. 10. 2008;10(10):638-45. [pmid: 18940744].
237 Gaspar LE. Stereotactic body radiation therapy for lung tumors: system-related issues and complications. Clin Lung Cancer. 01. 2007;8(4):233. [pmid: 17311686].
238 Gerber DE, Chan TA. Recent advances in radiation therapy.[summary for patients in Am Fam Physician 2008 Dec 1;78(11):1263–4; PMID: 19069019]. Am Fam Physician. 12. 1. 2008;78(11):1254-62. [pmid: 19069018].
239 Gerrard GE, Franks KN. Overview of the diagnosis and management of brain, spine, and meningeal metastases. J Neurol Neurosurg Psychiatry. 06. 2004;75(Suppl 2):ii37-ii42. [pmid: 15146038].
240 Gerszten PC, Burton SA, Belani CP, et al. Radiosurgery for the treatment of spinal lung metastases. Cancer. 12. 1. 2006;107(11):2653-61. [pmid: 17063501].
241 Gibbons JP, Mihailidis D, Worthington C, et al. Technical note: the effect of the 4-mm-collimator output factor on gamma knife dose distributions. J Appl Clin Med Phys. 2003;4(4):386-9. [pmid: 14604431].
242 Gibbs IC. Frameless image-guided intracranial and extracranial radiosurgery using the Cyberknife robotic system. Cancer Radiother. 09. 2006;10(5):283-7. [pmid: 16859948].
243 Gibbs IC, Chang SD. Radiosurgery and radiotherapy for sacral tumors. Neurosurg Focus. 08. 15. 2003;15(2):E8. [pmid: 15350039].
244 Gottlieb N. Radiotherapy technique tackles challenge of moving target. J Natl Cancer Inst. 03. 21. 2001;93(6):422. [pmid: 11259463].
245 Gottlieb N. Robotics and more: new technologies emerge for radiotherapy. J Natl Cancer Inst. 03. 21. 2001;93(6):421-3. [pmid: 11259462].
246 Grills IS, Fitch DL, Goldstein NS, et al. Clinicopathologic analysis of microscopic extension in lung adenocarcinoma: defining clinical target volume for radiotherapy. Int J Radiat Oncol Biol Phys. 10. 1. 2007;69(2):334-41. [pmid: 17570609].
247 Gross MW, Engenhart-Cabillic R. Normal tissue reactions after linac-based radiosurgery and stereotactic radiotherapy. Front Radiat Ther Oncol. 2002;37:140-50. [pmid: 11764656].
248 Gross MW, Spahn U, Engenhart-Cabillic R. Assessment of the accuracy of a conventional simulation for radiotherapy of head and skull base tumors. Technol Cancer Res Treat. 08. 2003;2(4):345-51. [pmid: 12892518].
249 Grutters JP, Pijls-Johannesma M, Ruysscher DD, et al. The cost-effectiveness of particle therapy in non-small cell lung cancer: exploring decision uncertainty and areas for future research. Cancer Treat Rev. 10. 2010;36(6):468-76. [pmid: 20303217].
250 Guckenberger M, Meyer J, Wilbert J, et al. Cone-beam CT based image-guidance for extracranial stereotactic radiotherapy of intrapulmonary tumors. Acta Oncol. 2006;45(7):897-906. [pmid: 16982556].
251 Guckenberger M, Meyer J, Wilbert J, et al. Intra-fractional uncertainties in cone-beam CT based image-guided radiotherapy (IGRT) of pulmonary tumors. Radiother Oncol. 04. 2007;83(1):57-64. [pmid: 17306394].
252 Guckenberger M, Wilbert J, Krieger T, et al. Mid-ventilation concept for mobile pulmonary tumors: internal tumor trajectory versus selective reconstruction of four-dimensional computed tomography frames based on external breathing motion. Int J Radiat Oncol Biol Phys. 06. 1. 2009;74(2):602-9. [pmid: 19427559].
253 Guckenberger M, Krieger T, Richter A, et al. Potential of image-guidance, gating and real-time tracking to improve accuracy in pulmonary stereotactic body radiotherapy. Radiother Oncol. 06. 2009;91(3):288-95. [pmid: 18835650].
254 Guckenberger M, Baier K, Polat B, et al. Dose-response relationship for radiation-induced pneumonitis after pulmonary stereotactic body radiotherapy. Radiother Oncol. 2010;97(1):65-70. [pmid: 20605245].
255 Guerrero M, Li XA. Extending the linear-quadratic model for large fraction doses pertinent to stereotactic radiotherapy. Phys Med Biol. 10. 21. 2004;49(20):4825-35. [pmid: 15566178].
256 Hadinger U, Thiele W, Wulf J. Extracranial stereotactic radiotherapy: evaluation of PTV coverage and dose conformity. Z Med Phys. 2002;12(4):221-9. [pmid: 12575435].
257 Haedinger U, Krieger T, Flentje M, et al. Influence of calculation model on dose distribution in stereotactic radiotherapy for pulmonary targets. Int J Radiat Oncol Biol Phys. 01. 1. 2005;61(1):239-49. [pmid: 15629617].
258 Hansen AT, Petersen JB, Hoyer M. Internal movement, set-up accuracy and margins for stereotactic body radiotherapy using a stereotactic body frame. Acta Oncol. 2006;45(7):948-52. [pmid: 16982562].
259 Hara W, Soltys SG, Gibbs IC. CyberKnife robotic radiosurgery system for tumor treatment. Expert Rev Anticancer Ther. 11. 2007;7(11):1507-15. [pmid: 18020920].
260 Heinzerling JH, Anderson JF, Papiez L, et al. Four-dimensional computed tomography scan analysis of tumor and organ motion at varying levels of abdominal compression during stereotactic treatment of lung and liver. Int J Radiat Oncol Biol Phys. 04. 1. 2008;70(5):1571-8. [pmid: 18374231].
261 Herbert CE, Ebert MA, Barclay D, et al. Effect of bite tray impression technique on relocation accuracy in frameless stereotactic radiotherapy. Med Dosim. 2003;28(1):27-30. [pmid: 12747615].
262 Hermann RM, Christiansen H, Schmidberger H, et al. Comment on ‘Dieckmann K, Georg D, Zehetmayer M, Bogner J, Georgopoulos M, Potter R. LINAC based stereotactic radiotherapy of uveal melanoma: 4 years clinical experience.’[Radiother Oncol 2003;67(2):199–206]. Radiother Oncol. 02. 2004;70(2):211. [pmid: 15028413].
263 Heron DE, Godette KD, Wynn RA, et al. Radiation medicine innovations for the new millenium. J Natl Med Assoc. 01. 2003;95(1):55-63. [pmid: 12656450].
264 Heron DE, Ferris RL, Karamouzis M, et al. Stereotactic body radiotherapy for recurrent squamous cell carcinoma of the head and neck: results of a phase I dose-escalation trial. Int J Radiat Oncol Biol Phys. 12. 1. 2009;75(5):1493-500. Epub 2009 May 21. [pmid: 19464819].
265 Heros RC. Radiosurgery and neurosurgeons. J Neurosurg. 08. 2005;103(2):203-5. [pmid: 16175846].
266 Hevezi JM. Emerging technology in cancer treatment: radiotherapy modalities. Oncology (Williston Park). 10. 2003;17(10):1445-56. [pmid: 14606366].
267 Hevezi JM. Current IGRT, SBRT, and SRS procedures and reimbursement. J Am Coll Radiol. 09. 2010;7(9):739-40. [pmid: 20816640].
268 Hinson WH, Kearns WT, Ellis TL, et al. Reducing set-up uncertainty in the Elekta Stereotactic Body Frame using Stealthstation software. Technol Cancer Res Treat. 06. 2007;6(3):181-6. [pmid: 17535026].
269 Hiraoka M, Matsuo Y, Nagata Y. Stereotactic body radiation therapy (SBRT) for early-stage lung cancer. Cancer Radiother. 01. 32. 2007;(1-2):11-5. [pmid: 17112758].
270 Hocht S, Stark R, Seiler F, et al. Proton or stereotactic photon irradiation for posterior uveal melanoma? A planning intercomparison. Strahlenther Onkol. 12. 2005;181(12):783-8. [pmid: 16362788].
271 Hogle WP. The state of the art in radiation therapy. Semin Oncol Nurs. 11. 2006;22(4):212-20. [pmid: 17095397].
272 Hoh DJ, Liu CY, Chen JC, et al. Chained lightning: part III--Emerging technology, novel therapeutic strategies, and new energy modalities for radiosurgery. Neurosurgery. 12. 2007;61(6):1111-29. [pmid: 18162890].
273 Holland J. New treatment modalities in radiation therapy. J Intraven Nurs. 03. 2001;24(2):95-101. [pmid: 11836839].
274 Holmes TW, Hudes R, Dziuba S, et al. Stereotactic image-guided intensity modulated radiotherapy using the HI-ART II helical tomotherapy system. Med Dosim. 2008;33(2):135-48. [pmid: 18456165].
275 Hoogeman MS, Nuyttens JJ, Levendag PC, et al. Time dependence of intrafraction patient motion assessed by repeat stereoscopic imaging. Int J Radiat Oncol Biol Phys. 02. 1. 2008;70(2):609-18. [pmid: 17996389].
276 Hoogeman M, Prevost JB, Nuyttens J, et al. Clinical accuracy of the respiratory tumor tracking system of the cyberknife: assessment by analysis of log files. Int J Radiat Oncol Biol Phys. 05. 1. 2009;74(1):297-303. [pmid: 19362249].
277 Horstmann GA, Schopgens H, van Eck AT, et al. First clinical experience with the automatic positioning system and Leksell gamma knife Model C. Technical note. J Neurosurg. 12. 2000;93(Suppl 3):193-7. [pmid: 11143247].
278 Hui SK, Das RK, Kapatoes J, et al. Helical tomotherapy as a means of delivering accelerated partial breast irradiation. Technol Cancer Res Treat. 12. 2004;3(6):639-46. [pmid: 15560722].
279 Huntzinger C, Friedman W, Bova F, et al. Trilogy image-guided stereotactic radiosurgery. Med Dosim. 2007;32(2):121-33. [pmid: 17472891].
280 Imura M, Yamazaki K, Shirato H, et al. Insertion and fixation of fiducial markers for setup and tracking of lung tumors in radiotherapy. Int J Radiat Oncol Biol Phys. 12. 1. 2005;63(5):1442-7. [pmid: 16109463].
281 Imura M, Yamazaki K, Kubota KC, et al. Histopathologic consideration of fiducial gold markers inserted for real-time tumor-tracking radiotherapy against lung cancer. Int J Radiat Oncol Biol Phys. 02. 1. 2008;70(2):382-4. [pmid: 17881147].
282 Inoue T, Katoh N, Aoyama H, et al. Clinical outcomes of stereotactic brain and/or body radiotherapy for patients with oligometastatic lesions. Jpn J Clin Oncol. 08. 2010;40(8):788-94. Epub 2010 Apr 20. [pmid: 20406944].
283 Isaksson M, Jalden J, Murphy MJ. On using an adaptive neural network to predict lung tumor motion during respiration for radiotherapy applications. Med Phys. 12. 2005;32(12):3801-9. [pmid: 16475780].
284 Jaffray D, Kupelian P, Djemil T, et al. Review of image-guided radiation therapy. Expert Rev Anticancer Ther. 2007;7(1):89-103. [pmid: 17187523].
285 Jamal K, Patel P, Sooriakumaran P. Minimally invasive surgical modalities in the management of localized prostate cancer. Expert Rev Anticancer Ther. 06. 2008;8(6):957-66. [pmid: 18533805].
286 Jawahar A, Jawahar LL, Nanda A, et al. Stereotactic radiosurgery using the Leksell Gamma Knife: current trends and future directives. Front Biosci. 01. 1. 2004;9:932-8. [pmid: 14766419].
287 Jeremic B, Becker G, Plasswilm L, et al. Activity of extracranial metastases as a prognostic factor influencing survival after radiosurgery of brain metastases. J Cancer Res Clin Oncol. 08. 2000;126(8):475-80. [pmid: 10961391].
288 Jin JY, Yin FF, Ryu S, et al. Dosimetric study using different leaf-width MLCs for treatment planning of dynamic conformal arcs and intensity-modulated radiosurgery. Med Phys. 02. 2005;32(2):405-11. [pmid: 15789586].
289 Jin JY, Kong FM, Chetty IJ, et al. Impact of fraction size on lung radiation toxicity: hypofractionation may be beneficial in dose escalation of radiotherapy for lung cancers. Int J Radiat Oncol Biol Phys. 03. 1. 2010;76(3):782-8. Epub 2009 Jul 4. [pmid: 19577855].
290 Joensuu H. Novel cancer therapies: more efficacy, less toxicity and improved organ preservation. Ann Med. 02. 2000;32(1):31-3. [pmid: 10711575].
291 Jozsef G, Luxton G, Formenti SC. Application of radiosurgery principles to a target in the breast: a dosimetric study. Med Phys. 05. 2000;27(5):1005-10. [pmid: 10841403].
292 Kassaee A, Das IJ, Tochner Z, et al. Modification of Gill-Thomas-Cosman frame for extracranial head-and-neck stereotactic radiotherapy. Int J Radiat Oncol Biol Phys. 11. 15. 2003;57(4):1192-5. [pmid: 14575852].
293 Katz AW, Carey-Sampson M, Muhs AG, et al. Hypofractionated stereotactic body radiation therapy (SBRT) for limited hepatic metastases. Int J Radiat Oncol Biol Phys. 03. 1. 2007;67(3):793-8. [pmid: 17197128].
294 Kavanagh BD, Timmerman RD. Stereotactic radiosurgery and stereotactic body radiation therapy: an overview of technical considerations and clinical applications. Hematol Oncol Clin North Am. 02. 2006;20(1):87-95. [pmid: 16580558].
295 Kavanagh BD, Timmerman RD, Benedict SH, et al. How should we describe the radiobiologic effect of extracranial stereotactic radiosurgery: equivalent uniform dose or tumor control probability. Med Phys. 03. 2003;30(3):321-4. [pmid: 12674231].
296 Kavanagh BD, Schefter TE, Cardenes HR, et al. Interim analysis of a prospective phase I/II trial of SBRT for liver metastases. Acta Oncol. 2006;45(7):848-55. [pmid: 16982549].
297 Kavanagh BD, Scheftera TE, Wersall PJ. Liver, renal, and retroperitoneal tumors: stereotactic radiotherapy. Front Radiat Ther Oncol. 2007;40:415-26. [pmid: 17641524].
298 Kavanagh BD, Kelly K, Kane M. The promise of stereotactic body radiation therapy in a new era of oncology. Front Radiat Ther Oncol. 2007;40:340-51. [pmid: 17641518].
299 Kavanagh B. Clinical experience shows that catastrophic late effects associated with ablative fractionation can be avoided by technological innovation. Semin Radiat Oncol. 10. 2008;18(4):223-8. [pmid: 18725107].
300 Kawaguchi O, Kunieda E, Fujii H, et al. Adenoid cystic carcinoma with hyperostosis after stereotactic radiosurgery. Radiat Med. 05. 2004;22(3):198-200. [pmid: 15287538].
301 Kelly PJ. Stereotactic surgery: what is past is prologue. Neurosurgery. 01. 2000;46(1):16-27. [pmid: 10626931].
302 Kenai H, Yamashita M, Nakamura T, et al. Tolerance dose in gamma knife surgery of lesions extending to the anterior visual pathway. J Neurosurg. 01. 2005;102(Suppl):230-3. [pmid: 15662816].
303 King CR, Lehmann J, Adler JR, et al. CyberKnife radiotherapy for localized prostate cancer: rationale and technical feasibility. Technol Cancer Res Treat. 02. 2003;2(1):25-30. [pmid: 12625751].
304 King CR, Brooks JD, Gill H, et al. Stereotactic body radiotherapy for localized prostate cancer: interim results of a prospective phase II clinical trial. Int J Radiat Oncol Biol Phys. 03. 15. 2009;73(4):1043-8. [pmid: 18755555].
305 King CR, Brooks JD, Gill H, et al. Stereotactic body radiotherapy for localized prostate cancer: interim results of a prospective phase II clinical trial. Int J Radiat Oncol Biol Phys. 03. 15. 2009;73(4):1043-8. [pmid: 18755555].
306 King CR, Lo A, Kapp DS. Testicular dose from prostate cyberknife: a cautionary note. Int J Radiat Oncol Biol Phys. 02. 1. 2009;73(2):636-7. [pmid: 19147028].
307 Kitamura K, Shirato H, Shimizu S, et al. Registration accuracy and possible migration of internal fiducial gold marker implanted in prostate and liver treated with real-time tumor-tracking radiation therapy (RTRT). Radiother Oncol. 03. 2002;62(3):275-81. [pmid: 12175558].
308 Kitamura K, Shirato H, Seppenwoolde Y, et al. Three-dimensional intrafractional movement of prostate measured during real-time tumor-tracking radiotherapy in supine and prone treatment positions. Int J Radiat Oncol Biol Phys. 08. 1. 2002;53(5):1117-23. [pmid: 12128110].
309 Kitamura K, Shirato H, Seppenwoolde Y, et al. Tumor location, cirrhosis, and surgical history contribute to tumor movement in the liver, as measured during stereotactic irradiation using a real-time tumor-tracking radiotherapy system. Int J Radiat Oncol Biol Phys. 05. 1. 2003;56(1):221-8. [pmid: 12694842].
310 Koga T, Maruyama K, Igaki H, et al. The value of image coregistration during stereotactic radiosurgery. Acta Neurochir (Wien). 05. 2009;151(5):465-71. [pmid: 19319470].
311 Kommu SS, Andrews RJ, Mah RW. Real-time multiple microsensor tissue recognition and its potential application in the management of prostate cancer. BJU Int. 02. 2006;97(2):222-3. [pmid: 16430616].
312 Kondziolka D, Lunsford LD, Witt TC, et al. The future of radiosurgery: radiobiology, technology, and applications. Surg Neurol. 12. 2000;54(6):406-14. [pmid: 11240166].
313 Kondziolka D, Lunsford LD, Loeffler JS, et al. Radiosurgery and radiotherapy: observations and clarifications. J Neurosurg. 10. 2004;101(4):585-9. [pmid: 15481710].
314 Kondziolka D, Lunsford LD, Flickinger JC, et al. Emerging indications in stereotactic radiosurgery. Clin Neurosurg. 2005;52:229-33. [pmid: 16626075].
315 Kondziolka D, Niranjan A, Lunsford LD, et al. Radiobiology of radiosurgery. Prog Neurol Surg. 2007;20:16-27. [pmid: 17317973].
316 Kontrisova K, Stock M, Dieckmann K, et al. Dosimetric comparison of stereotactic body radiotherapy in different respiration conditions: a modeling study. Radiother Oncol. 10. 2006;81(1):97-104. [pmid: 16962675].
317 Koong AC, Le QT, Ho A, et al. Phase I study of stereotactic radiosurgery in patients with locally advanced pancreatic cancer. Int J Radiat Oncol Biol Phys. 03. 15. 2004;58(4):1017-21. [pmid: 15001240].
318 Koong AC, Christofferson E, Le QT, et al. Phase II study to assess the efficacy of conventionally fractionated radiotherapy followed by a stereotactic radiosurgery boost in patients with locally advanced pancreatic cancer. Int J Radiat Oncol Biol Phys. 10. 1. 2005;63(2):320-3. [pmid: 16168826].
319 Kopek N, Holt MI, Hansen AT, et al. Stereotactic body radiotherapy for unresectable cholangiocarcinoma. Radiother Oncol. 01. 2010;94(1):47-52. [pmid: 19963295].
320 Korreman S, Mostafavi H, Le QT, et al. Comparison of respiratory surrogates for gated lung radiotherapy without internal fiducials. Acta Oncol. 2006;45(7):935-42. [pmid: 16982560].
321 Kresl JJ. St. Joseph’s Hospital and Barrow Neurological Institute stereotactic radiotherapy experience: Comparison of Gamma Knife and CyberKnife. Nowotwory. 2006;56(2):125-30.
322 Kunieda E, Kawaguchi O, Saitoh H, et al. Measurement of beam-axis displacement from the isocenter during three-dimensional conformal radiosurgery with a micro-multileaf collimator. Radiother Oncol. 01. 2004;70(1):45-8. [pmid: 15036851].
323 Kunieda E, Deloar HM, Kishitani N, et al. Variation of dose distribution of stereotactic radiotherapy for small-volume lung tumors under different respiratory conditions. Phys Med. 12. 2008;24(4):204-11. [pmid: 18396083].
324 Kunzler T, Grezdo J, Bogner J, et al. Registration of DRRs and portal images for verification of stereotactic body radiotherapy: a feasibility study in lung cancer treatment. Phys Med Biol. 04. 21. 2007;52(8):2157-70. [pmid: 17404461].
325 Kupferman ME, Hanna EY. Paragangliomas of the head and neck. Curr Oncol Rep. 03. 2008;10(2):156-61. [pmid: 18377829].
326 Laigle-Donadey F, Taillibert S, Martin-Duverneuil N, et al. Skull-base metastases. J Neurooncol. 10. 2005;75(1):63-9. [pmid: 16215817].
327 Langner UW, Keall PJ. Accuracy in the localization of thoracic and abdominal tumors using respiratory displacement, velocity, and phase. Med Phys. 02. 2009;36(2):386-93. [pmid: 19291977].
328 Larre S, Salomon L, Abbou CC. Choices for surgery. Recent Results Cancer Res. 2007;175:163-78. [pmid: 17432559].
329 Lartigau E, Mirabel X, Prevost JB, et al. Extracranial stereotactic radiotherapy: preliminary results with the CyberKnife. Onkologie. 04. 2009;32(4):209-15. [pmid: 19372719].
330 Lawson JD, Fox T, Waller AF, et al. Multileaf collimator-based linear accelerator radiosurgery: five-year efficiency analysis. J Am Coll Radiol. 03. 2009;6(3):190-3. [pmid: 19248995].
331 Lax I, Panettieri V, Wennberg B, et al. Dose distributions in SBRT of lung tumors: Comparison between two different treatment planning algorithms and Monte-Carlo simulation including breathing motions. Acta Oncol. 2006;45(7):978-88. [pmid: 16982567].
332 Leavitt DD, Watson G, Tobler M, et al. Intensity-modulated radiosurgery/radiotherapy using a micromultileaf collimator. Med Dosim. 2001;26(2):143-50. [pmid: 11444516].
333 Lee EK, Fox T, Crocker I. Optimization of radiosurgery treatment planning via mixed integer programming. Med Phys. 05. 2000;27(5):995-1004. [pmid: 10841402].
334 Lee WR. Extreme hypofractionation for prostate cancer. Expert Rev Anticancer Ther. 2009;9(1):61-5. [pmid: 19105707].
335 Leksell D. Epilogue: The future of radiosurgery. 2007:388-91.
336 Li K, Ma L. A constrained tracking algorithm to optimize plug patterns in multiple isocenter gamma knife radiosurgery planning. Med Phys. 10. 2005;32(10):3132-5. [pmid: 16279066].
337 Liao R, Williams JA, Myers L, et al. Optimization of multiple-isocenter treatment planning for linac-based stereotactic radiosurgery. Comput Aided Surg. 2000;5(4):220-33. [pmid: 11029156].
338 Lillard A. SBRT - the new treatment of choice. Imaging Technol News. 09. 2008;28:31.
339 Lind CR, Costello SA, Mathur S, et al. Stereotactic radiosurgery in New Zealand. N Z Med J. 04. 27. 2001;114(1130):182-4. [pmid: 11396666].
340 Lindquist C, Paddick I. The Leksell Gamma Knife Perfexion and comparisons with its predecessors. Neurosurgery. 09. 2007;61(3 Suppl):130-40. [pmid: 17876243].
341 Lindvall P, Bergstrom P, Lofroth PO, et al. Reproducibility and geometric accuracy of the Fixster system during hypofractionated stereotactic radiotherapy. Radiat Oncol. 2008;3:16. [pmid: 18507861].
342 Linskey ME, Johnstone PA. Radiation tolerance of normal temporal bone structures: implications for gamma knife stereotactic radiosurgery. Int J Radiat Oncol Biol Phys. 09. 1. 2003;57(1):196-200. [pmid: 12909233].
343 Linthout N, Bral S, Van dVI, et al. Treatment delivery time optimization of respiratory gated radiation therapy by application of audio-visual feedback. Radiother Oncol. 06. 2009;91(3):330-5. [pmid: 19368987].
344 Liu R, Wagner TH, Buatti JM, et al. Geometrically based optimization for extracranial radiosurgery. Phys Med Biol. 03. 21. 2004;49(6):987-96. [pmid: 15104321].
345 Livi L, Paiar F, Buonamici FB, et al. Accelerated intensity-modulated external radiotherapy as a new technical approach to treat the index quadrant after conserving surgery in early breast cancer: a preliminary study. Tumori. 05. 2005;91(3):227-32. [pmid: 16206645].
346 Lo SS, Cardenes HR, Teh BS, et al. Stereotactic body radiation therapy for nonpulmonary primary tumors. Expert Rev Anticancer Ther. 12. 2008;8(12):1939-51. [pmid: 19046114].
347 Lo SS, Fakiris AJ, Teh BS, et al. Stereotactic body radiation therapy for oligometastases. Expert Rev Anticancer Ther. 05. 2009;9(5):621-35. [pmid: 19445579].
348 Lomax NJ, Scheib SG. Quantifying the degree of conformity in radiosurgery treatment planning. Int J Radiat Oncol Biol Phys. 04. 1. 2003;55(5):1409-19. [pmid: 12654454].
349 Lu XQ, Shanmugham LN, Mahadevan A, et al. Organ deformation and dose coverage in robotic respiratory-tracking radiotherapy. Int J Radiat Oncol Biol Phys. 05. 1. 2008;71(1):281-9. [pmid: 18406892].
350 Ma L, Chin LS, DiBiase SJ, et al. Concomitant boost of stratified target area with gamma knife radiosurgery: a treatment planning study. Am J Clin Oncol. 08. 2003;26(4):e100-e105. [pmid: 12902906].
351 Maarouf M, Treuer H, Kocher M, et al. Radiation exposure of extracranial organs at risk during stereotactic linac radiosurgery. Strahlenther Onkol. 07. 2005;181(7):463-7. [pmid: 15995840].
352 Macdermed DM, Weichselbaum RR, Salama JK. A rationale for the targeted treatment of oligometastases with radiotherapy. J Surg Oncol. 09. 1. 2008;98(3):202-6. [pmid: 18618604].
353 Martin A, Gaya A. Stereotactic body radiotherapy: a review. Clin Oncol (R Coll Radiol). 04. 2010;22(3):157-72. Epub 2010 Jan 25. [pmid: 20092981].
354 Matsumoto Y, Horiike S, Fujimoto Y, et al. Effectiveness and limitation of gamma knife radiosurgery for relapsed central nervous system lymphoma: a retrospective analysis in one institution. Int J Hematol. 05. 2007;85(4):333-7. [pmid: 17483078].
355 McDermott LN, Wendling M, Sonke JJ, et al. Anatomy changes in radiotherapy detected using portal imaging. Radiother Oncol. 05. 2006;79(2):211-7. [pmid: 16698097].
356 McGarry RC, Papiez L, Williams M, et al. Stereotactic body radiation therapy of early-stage non-small-cell lung carcinoma: phase I study. Int J Radiat Oncol Biol Phys. 11. 15. 2005;63(4):1010-5. [pmid: 16115740].
357 Meeks SL, Buatti JM, Bouchet LG, et al. Ultrasound-guided extracranial radiosurgery: technique and application. Int J Radiat Oncol Biol Phys. 03. 15. 2003;55(4):1092-101. [pmid: 12605989].
358 Mell LK, Mundt AJ. Radiation therapy in the elderly. Cancer J. 11. 2005;11(6):495-505. [pmid: 16393484].
359 Meretoja TJ, Von Smitten KA, Kuokkanen HO, et al. Complications of skin-sparing mastectomy followed by immediate breast reconstruction: A prospective randomized study comparing high-frequency radiosurgery with conventional diathermy. Ann Plast Surg. 01. 2008;60(1):24-8. [pmid: 18281791].
360 Mery CM, Cooke DT, Chandra V, et al. The road to innovation: emerging technologies in surgery. Bull Am Coll Surg. 07. 2007;92(7):19-33. [pmid: 17691613].
361 Meyer JL, Verhey L, Xia P, et al. New technologies in the radiotherapy clinic. Front Radiat Ther Oncol. 2007;40:1-17. [pmid: 17641499].
362 Meyer JL, Leibel S, Roach M, et al. New technologies for the radiotherapy of prostate cancer. A discussion of clinical treatment programs. Front Radiat Ther Oncol. 2007;40:315-37. [pmid: 17641517].
363 Mignano JE, Engler MJ, Tsai JS, et al. Comparison of radiobiologic modeling for one- and two-isocenter dose distributions applied to ellipsoidal radiosurgery targets. Int J Radiat Oncol Biol Phys. 03. 1. 2001;49(3):833-7. [pmid: 11172967].
364 Minn AY, Schellenberg D, Maxim P, et al. Pancreatic tumor motion on a single planning 4D-CT does not correlate with intrafraction tumor motion during treatment. Am J Clin Oncol. 08. 2009;32(4):364-8. [pmid: 19398901].
365 Molla M, Escude L, Nouet P, et al. Fractionated stereotactic radiotherapy boost for gynecologic tumors: an alternative to brachytherapy. Int J Radiat Oncol Biol Phys. 05. 1. 2005;62(1):118-24. [pmid: 15850911].
366 Morgia G, De Renzis C. CyberKnife in the treatment of prostate cancer: a revolutionary system. Eur Urol. 07. 2009;56(1):40-2. Epub 2009 Feb 23. [pmid: 19246151].
367 Muacevic A, Wowra B, Kreth FW, et al. Radiosurgery in renal cell carcinoma. J Neurosurg. 08. 1. 2003;99(2):441-2. [pmid: 12924727].
368 Muacevic A, Jess-Hempen A, Tonn JC, et al. Clinical quality standards for gamma knife radiosurgery--the Munich protocol. Acta Neurochir Suppl. 2004;91:25-32. [pmid: 15707023].
369 Muller K, Nowak PJ, Luyten GP, et al. A modified relocatable stereotactic frame for irradiation of eye melanoma: design and evaluation of treatment accuracy. Int J Radiat Oncol Biol Phys. 01. 1. 2004;58(1):284-91. [pmid: 14697450].
370 Murphy MJ. Tracking moving organs in real time. Semin Radiat Oncol. 01. 2004;14(1):91-100. [pmid: 14752737].
371 Murphy MJ, Martin D, Whyte R, et al. The effectiveness of breath-holding to stabilize lung and pancreas tumors during radiosurgery. Int J Radiat Oncol Biol Phys. 06. 1. 2002;53(2):475-82. [pmid: 12023152].
372 Murphy MJ, Chang SD, Gibbs IC, et al. Patterns of patient movement during frameless image-guided radiosurgery. Int J Radiat Oncol Biol Phys. 04. 1. 2003;55(5):1400-8. [pmid: 12654453].
373 Murphy MJ. Intrafraction geometric uncertainties in frameless image-guided radiosurgery. Int J Radiat Oncol Biol Phys. 04. 1. 2009;73(5):1364-8. [pmid: 19084349].
374 Murray B, Forster K, Timmerman R. Frame-based immobilization and targeting for stereotactic body radiation therapy. Med Dosim. 2007;32(2):86-91. [pmid: 17472887].
375 Naff NJ. CyberKnife radiosurgery in neurosurgical practice. Neurosurg Q. 12. 2007;17(4):273-82.
376 Nagata Y, Matsuo Y, Takayama K, et al. Current status of stereotactic body radiotherapy for lung cancer. Int J Clin Oncol. 02. 2007;12(1):3-7. [pmid: 17380434].
377 Nakagawa K, Tago M, Shibata K, et al. Intercomparison of dose distribution between gamma knife and C-arm-mounted linac. Radiat Med. 07. 2003;21(4):178-82. [pmid: 14514125].
378 Nakaji P, Spetzler RF. Innovations in surgical approach: the marriage of technique, technology, and judgment. Clin Neurosurg. 2004;51:177-85. [pmid: 15571143].
379 Nakamura JL, Verhey LJ, Smith V, et al. Dose conformity of gamma knife radiosurgery and risk factors for complications. Int J Radiat Oncol Biol Phys. 12. 1. 2001;51(5):1313-9. [pmid: 11728692].
380 Nedzi LA. The implementation of ablative hypofractionated radiotherapy for stereotactic treatments in the brain and body: observations on efficacy and toxicity in clinical practice. Semin Radiat Oncol. 10. 2008;18(4):265-72. [pmid: 18725114].
381 Nguyen NP, Garland L, Welsh J, et al. Can stereotactic fractionated radiation therapy become the standard of care for early stage non-small cell lung carcinoma. Cancer Treat Rev. 12. 2008;34(8):719-27. [pmid: 18657910].
382 Nieder C, Pawinski A, Haukland E, et al. Estimating need for palliative external beam radiotherapy in adult cancer patients. Int J Radiat Oncol Biol Phys. 01. 1. 2010;76(1):207-11. [pmid: 19362788].
383 Niranjan A, Lunsford LD. Radiosurgery: where we were, are, and may be in the third millennium. Neurosurgery. 03. 2000;46(3):531-43. [pmid: 10719848].
384 Niranjan A, Maitz AH, Kondziolka D, et al. Radiosurgery: Current techniques. Tech Neurosurg. 2003;9(3):119-27.
385 Niranjan A, Maitz AH, Lunsford A, et al. Radiosurgery techniques and current devices. 2007:50-67.
386 Niranjan A, Maitz AH, Lunsford A, et al. Radiosurgery techniques and current devices. Prog Neurol Surg. 2007;20:50-67. [pmid: 17317976].
387 Less invasive surgery for prostate cancer. Harv Mens Health Watch. 12. 2003;8(5):6-8. [pmid: 14690970].
388 Proceedings of the 3rd Acta Oncologica Symposium on Stereotactic Body Radiotherapy. June 15–17, 2006. Copenhagen, Denmark. Acta Oncol. 2006;45(7):771-994.
389 Current world literature. Kidney cancer. Curr Opin Urol. 09. 2007;17(5):376-8. [pmid: 17762634].
390 Update: minimal access surgery. ANZ J Surg. 09. 2007;77(9):792-5. [pmid: 17685961].
391 Noda S, Lautenschlaeger T, Siedow MR, et al. Technological advances in radiation oncology for central nervous system tumors. Semin Radiat Oncol. 07. 2009;19(3):179-86. [pmid: 19464633].
392 Okunieff P, Petersen AL, Philip A, et al. Stereotactic Body Radiation Therapy (SBRT) for lung metastases. Acta Oncol. 2006;45(7):808-17. [pmid: 16982544].
393 Onishi H, Kuriyama K, Komiyama T, et al. A new irradiation system for lung cancer combining linear accelerator, computed tomography, patient self-breath-holding, and patient-directed beam-control without respiratory monitoring devices. Int J Radiat Oncol Biol Phys. 05. 1. 2003;56(1):14-20. [pmid: 12694819].
394 Orecchia R. Image-guided radiotherapy and hypofractionation in lung cancer. J Thorac Oncol. 05. 2007;2(5 Suppl):S42-S44. [pmid: 17457233].
395 Pan HC, Cheng FC, Sun MH, et al. Prediction of volumetric data errors in patients treated with gamma knife radiosurgery. Stereotact Funct Neurosurg. 2007;85(4):184-91. [pmid: 17389818].
396 Pang LJ. Radiation oncology update. Hawaii Med J. 05. 2003;62(5):109-10. [pmid: 12806792].
397 Papiez L, Timmerman R. Hypofractionation in radiation therapy and its impact. Med Phys. 01. 2008;35(1):112-8. [pmid: 18293568].
398 Papiez L, Timmerman R, DesRosiers C, et al. Extracranial Stereotactic Radioablation: Physical Principles. Acta Oncol. 2003;42(8):882-94. [pmid: 14968949].
399 Park C, Papiez L, Zhang S, et al. Universal survival curve and single fraction equivalent dose: useful tools in understanding potency of ablative radiotherapy. Int J Radiat Oncol Biol Phys. 03. 1. 2008;70(3):847-52. [pmid: 18262098].
400 Parman CC. Stereotactic radiosurgery. J Oncol Manage. 03. 2004;13(2):7-8. [pmid: 15180111].
401 Pass H. The mets, the scalpels, and possibly the beams. J Thorac Oncol. 11. 2008;3(11):1211-2. [pmid: 18978554].
402 Pawlicki T, Cotrutz C, King C. Prostate cancer therapy with stereotactic body radiation therapy. Front Radiat Ther Oncol. 2007;40:395-406. [pmid: 17641522].
403 Pennathur A, Luketich JD, Burton S, et al. Stereotactic radiosurgery for the treatment of lung neoplasm: initial experience. Ann Thorac Surg. 05. 2007;83(5):1820-4. [pmid: 17462406].
404 Petersch B, Bogner J, Dieckmann K, et al. Automatic real-time surveillance of eye position and gating for stereotactic radiotherapy of uveal melanoma. Med Phys. 12. 2004;31(12):3521-7. [pmid: 15651635].
405 Petrovich Z, Yu C. Frame-based and frameless stereotactic radiosurgery for intracranial and extracranial tumors. Nowotwory. 2003;53(5):508-16.
406 Pishvaian AC, Collins B, Gagnon G, et al. EUS-guided fiducial placement for CyberKnife radiotherapy of mediastinal and abdominal malignancies. Gastrointest Endosc. 09. 2006;64(3):412-7. [pmid: 16923491].
407 Khrizman P, Small W Jr, Dawson L, et al. The use of stereotactic body radiation therapy in gastrointestinal malignancies in locally advanced and metastatic settings. Clin Colorectal Cancer. 07. 2010;9(3):136-43. [pmid: 20643617].
408 Poll JJ, Hoogeman MS, Prevost JB, et al. Reducing monitor units for robotic radiosurgery by optimized use of multiple collimators. Med Phys. 06. 2008;35(6):2294-9. [pmid: 18649461].
409 Pollock BE. An evidence-based medicine review of stereotactic radiosurgery. Prog Neurol Surg. 2006;19:152-70. [pmid: 17033153].
410 Pott PP, Scharf HP, Schwarz ML. Today’s state of the art in surgical robotics*. Comput Aided Surg. 03. 2005;10(2):101-32. [pmid: 16298921].
411 Potters L, Timmerman R, Larson D. Stereotactic body radiation therapy. J Am Coll Radiol. 08. 2005;2(8):676-80. [pmid: 17411904].
412 Prabhu SS, Demonte F. Treatment of skull base tumors. Curr Opin Oncol. 05. 2003;15(3):209-12. [pmid: 12778013].
413 Prevost JB, Nuyttens JJ, Hoogeman MS, et al. Endovascular coils as lung tumour markers in real-time tumour tracking stereotactic radiotherapy: Preliminary results. Eur Radiol. 08. 2008;18(8):1569-76. [pmid: 18389249].
414 Prevost JB, Voet P, Hoogeman M, et al. Four-dimensional stereotactic radiotherapy for early stage non-small cell lung cancer: a comparative planning study. Technol Cancer Res Treat. 02. 2008;7(1):27-33. [pmid: 18198921].
415 Purdie TG, Moseley DJ, Bissonnette JP, et al. Respiration correlated cone-beam computed tomography and 4DCT for evaluating target motion in Stereotactic Lung Radiation Therapy. Acta Oncol. 2006;45(7):915-22. [pmid: 16982558].
416 Quang TS, Wallner KE, Herstein PR, et al. Technologic evolution in the treatment of prostate cancer. Clinical, financial, and legal implications for managed care organizations. Oncology (Huntingt). 11. 2007;21(13):1598-600. 1602. [pmid: 18179049].
417 Quinn AM. CyberKnife: a robotic radiosurgery system. Clin J Oncol Nurs. 05. 2002;6(3):149. 156. [pmid: 11998608].
418 Rassiah-Szegedi P, Salter BJ, Fuller CD, et al. Monte Carlo characterization of target doses in stereotactic body radiation therapy (SBRT). Acta Oncol. 2006;45(7):989-94. [pmid: 16982568].
419 Ratto GB, Cafferata MA, Scolaro T, et al. Phase II study of combined immunotherapy, chemotherapy, and radiotherapy in the postoperative treatment of advanced non-small-cell lung cancer. J Immunother. 2000. 01. 1991;23(1):161-7. [pmid: 10687149].
420 Regine WF. Foreword: stereotactic radiosurgery - state of the art. Technol Cancer Res Treat. 04. 2003;2(2):77-8.
421 Regis J, Tamura M, Guillot C, et al. Radiosurgery with the world’s first fully robotized Leksell Gamma Knife PerfeXion in clinical use: a 200-patient prospective, randomized, controlled comparison with the Gamma Knife 4C. Neurosurgery. 02. 2009;64(2):346-55. [pmid: 19190462].
422 Riboldi M, Baroni G, Spadea MF, et al. Robust frameless stereotactic localization in extra-cranial radiotherapy. Med Phys. 04. 2006;33(4):1141-52. [pmid: 16696492].
423 Rock JP, Ryu S, Yin FF. Novalis radiosurgery for metastatic spine tumors. Neurosurg Clin North Am. 10. 2004;15(4):503-9. [pmid: 15450885].
424 Rockhill JK. Advances in radiation therapy for oncologic pain. Curr Pain Headache Rep. 08. 2007;11(4):270-5. [pmid: 17686390].
425 Romanelli P, Chang SD, Koong A, et al. Extracranial radiosurgery using the CyberKnife. Tech Neurosurg. 2003;9(3):226-31.
426 Romanelli P, Schweikard A, Schlaefer A, et al. Computer aided robotic radiosurgery. Comput Aided Surg. 07. 2006;11(4):161-74. [pmid: 17060075].
427 Romanelli P, Schaal DW, Adler JR. Image-guided radiosurgical ablation of intra- and extra-cranial lesions. Technol Cancer Res Treat. 08. 2006;5(4):421-8. [pmid: 16866572].
428 Rosahl SK, Roser F, Samii M. Renal metastasis. J Neurosurg. 04. 2002;96(4):804-5. [pmid: 11990825].
429 Rosenzweig KE, Amols H, Ling CC. New radiotherapy technologies. Semin Surg Oncol. 2003;21(3):190-5. [pmid: 14508852].
430 Rosenzweig KE, Movsas B, Bradley J, et al. ACR appropriateness criteria on nonsurgical treatment for non-small-cell lung cancer: poor performance status or palliative intent, J Am Coll Radiol. 02. 2009;6(2):85-95. [pmid: 19179235].
431 Rousseau J, Gibon D. Optimizing for the Gamma knife. Int J Radiat Oncol Biol Phys. 09. 1. 2000;48(2):613. [pmid: 11012309].
432 Rutten I, Deneufbourg JM. Radiotherapy in pediatric head and neck tumours. Acta Otorhinolaryngol Belg. 2000;54(1):1-6. [pmid: 10719587].
433 Ryken TC, Meeks SL, Pennington EC, et al. Initial clinical experience with frameless stereotactic radiosurgery: analysis of accuracy and feasibility. Int J Radiat Oncol Biol Phys. 11. 15. 2001;51(4):1152-8. [pmid: 11704340].
434 Samper PM, Lopez Carrizosa MC, Perez CA, et al. Impact of neoadjuvant hormonal therapy on dose-volume histograms in patients with localized prostate cancer under radical radiation therapy. Clin Transl Oncol. 08. 2006;8(8):599-605. [pmid: 16952849].
435 Sankaranarayanan V, Ganesan S, Oommen S, et al. Study on dosimetric parameters for stereotactic radiosurgery and intensity-modulated radiotherapy. Med Dosim. 2003;28(2):85-90. [pmid: 12804705].
436 Sarfaraz M. CyberKnife robotic arm stereotactic radiosurgery. J Am Coll Radiol. 08. 2007;4(8):563-5. [pmid: 17660122].
437 Sasai K, Nagata Y, Hiraoka M. Is the linear-quadratic formula available in stereotactic radiosurgery or hypofractionated radiotherapy? The problem of the uncertainty of the alpha/beta ratio in the LQ formula. Int J Radiat Oncol Biol Phys. 07. 1. 2000;47(4):1157-8.
438 Saunders JE. On stereotactic radiosurgery. Hear J. 09. 2007;60(9):70.
439 Savides TJ. EUS-guided fine-needle insertion of radiopaque fiducials: X marks the spot. Gastrointest Endosc. 09. 2006;64(3):418-9. [pmid: 16923492].
440 Saw CB, Chen H, Wagner H Jr. Implementation of fiducial-based image registration in the Cyberknife robotic system. Med Dosim. 2008;33(2):156-60. [pmid: 18456167].
441 Sawrie SM, Fiveash JB, Caudell JJ. Stereotactic body radiation therapy for liver metastases and primary hepatocellular carcinoma: normal tissue tolerances and toxicity. Cancer Control. 04. 2010;17(2):111-9. [pmid: 20404794].
442 Schefter TE, Kavanagh BD, Timmerman RD, et al. A phase I trial of stereotactic body radiation therapy (SBRT) for liver metastases. Int J Radiat Oncol Biol Phys. 08. 1. 2005;62(5):1371-8. [pmid: 16029795].
443 Scheib SG, Gianolini S, Lomax NJ, et al. High precision radiosurgery and technical standards. Acta Neurochir Suppl. 2004;91:9-23. [pmid: 15707022].
444 Schellenberg D, Quon A, Minn AY, et al. 18Fluorodeoxyglucose PET is prognostic of progression-free and overall survival in locally advanced pancreas cancer treated with stereotactic radiotherapy. Int J Radiat Oncol Biol Phys. 08. 1. 2010;77(5):1420-5. [pmid: 20056345].
445 Schlaefer A, Fisseler J, Dieterich S, et al. Feasibility of four-dimensional conformal planning for robotic radiosurgery. Med Phys. 12. 2005;32(12):3786-92. [pmid: 16475778].
446 Schweikard A, Glosser G, Bodduluri M, et al. Robotic motion compensation for respiratory movement during radiosurgery. Comput Aided Surg. 2000;5(4):263-77. [pmid: 11029159].
447 Schweikard A, Shiomi H, Adler J. Respiration tracking in radiosurgery. Med Phys. 10. 2004;31(10):2738-41. [pmid: 15543778].
448 Scorsetti M, Bignardi M. Conformal and stereotactic radiotherapy in hepatocellular carcinoma. Ann Ital Chir. 03. 2008;79(2):107-10. [pmid: 18727272].
449 Seki S, Kunieda E, Takeda A, et al. Differences in the definition of internal target volumes using slow CT alone or in combination with thin-slice CT under breath-holding conditions during the planning of stereotactic radiotherapy for lung cancer. Radiother Oncol. 12. 2007;85(3):443-9. [pmid: 17981350].
450 Senan S, Haasbeek NJ, Smit EF, et al. Stereotactic radiotherapy for centrally located early-stage lung tumors. J Clin Oncol. 02. 1. 2007;25(4):464. [pmid: 17264351].
451 Seppenwoolde Y, Shirato H, Kitamura K, et al. Precise and real-time measurement of 3D tumor motion in lung due to breathing and heartbeat, measured during radiotherapy. Int J Radiat Oncol Biol Phys. 07. 15. 2002;53(4):822-34. [pmid: 12095547].
452 Sharma A, Wong D, Weidlich G, et al. Non-invasive stereotactic radiosurgery (CyberHeart) for the creation of ablation lesions in the atrium. Heart Rhythm. 06. 2010;7(6):802-10. Epub 2010 Feb 13. [pmid: 20156591].
453 Shepard DM, Ferris MC, Ove R, et al. Inverse treatment planning for Gamma Knife radiosurgery. Med Phys. 12. 2000;27(12):2748-56. [pmid: 11190958].
454 Sherwood JT, Brock MV. Lung cancer: new surgical approaches. Respirology. 05. 2007;12(3):326-32. [pmid: 17539834].
455 Shibuya H, Tsujii H. The structural characteristics of radiation oncology in Japan in 2003. Int J Radiat Oncol Biol Phys. 08. 1. 2005;62(5):1472-6. [pmid: 16029809].
456 Shirato H, Harada T, Harabayashi T, et al. Feasibility of insertion/implantation of 2.0-mm-diameter gold internal fiducial markers for precise setup and real-time tumor tracking in radiotherapy. Int J Radiat Oncol Biol Phys. 05. 1. 2003;56(1):240-7. [pmid: 12694845].
457 Shirato H, Suzuki K, Sharp GC, et al. Speed and amplitude of lung tumor motion precisely detected in four-dimensional setup and in real-time tumor-tracking radiotherapy. Int J Radiat Oncol Biol Phys. 03. 15. 2006;64(4):1229-36. [pmid: 16504762].
458 Shirato H, Shimizu S, Kitamura K, et al. Organ motion in image-guided radiotherapy: lessons from real-time tumor-tracking radiotherapy. Int J Clin Oncol. 02. 2007;12(1):8-16. [pmid: 17380435].
459 Shiu AS, Chang EL, Ye JS, et al. Near simultaneous computed tomography image-guided stereotactic spinal radiotherapy: an emerging paradigm for achieving true stereotaxy. Int J Radiat Oncol Biol Phys. 11. 1. 2003;57(3):605-13. [pmid: 14529763].
460 Shoshan Y, Wygoda M, Umansky F. Stereotactic radiosurgery and fractionated stereotactic radiotherapy: background, definitions, applications. Isr Med Assoc J. 09. 2005;7(9):597-9. [pmid: 16190486].
461 Shrieve DC, Klish M, Wendland MM, et al. Basic principles of radiobiology, radiotherapy, and radiosurgery. Neurosurg Clin North Am. 10. 2004;15(4):467-79. [pmid: 15450882].
462 Siddiqui F, Patel M, Khan M, et al. Stereotactic body radiation therapy for primary, recurrent, and metastatic tumors in the head-and-neck region. Int J Radiat Oncol Biol Phys. 07. 15. 2009;74(4):1047-53. [pmid: 19327895].
463 Silvano G. New radiation techniques for treatment of locally advanced non-small cell lung cancer (NSCLC). Ann Oncol. 03. 2006;17(Suppl 2):ii34-ii35. [pmid: 16608978].
464 Singletary SE. Minimally invasive techniques in breast cancer treatment. Semin Surg Oncol. 04. 2001;20(3):246-50. [pmid: 11523110].
465 Siva S, MacManus M, Ball D. Stereotactic radiotherapy for pulmonary oligometastases: a systematic review. J Thorac Oncol. 07. 2010;5(7):1091-9. [pmid: 20479693].
466 Slotman BJ, Cottier B, Bentzen SM, et al. Overview of national guidelines for infrastructure and staffing of radiotherapy. ESTRO-QUARTS: work package 1. Radiother Oncol. 06. 2005;75(3):349-54. [pmid: 15893832].
467 Slotman BJ, Lagerwaard FJ, Senan S. 4D imaging for target definition in stereotactic radiotherapy for lung cancer. Acta Oncol. 2006;45(7):966-72. [pmid: 16982565].
468 Smink KA, Schneider SM. Overview of stereotactic body radiotherapy and the nursing role. Clin J Oncol Nurs. 12. 2008;12(6):889-93. [pmid: 19064382].
469 Smit BJ. Radiosurgery in South Africa. S Afr Med J. 04. 2000;90(4):355-6. [pmid: 10957916].
470 Smith V, Chuang CF. The Cyberknife: practical experience with treatment planning and delivery. Front Radiat Ther Oncol. 2007;40:143-61. [pmid: 17641507].
471 Snell JW, Sheehan J, Stroila M, et al. Assessment of imaging studies used with radiosurgery: a volumetric algorithm and an estimation of its error. Technical note. J Neurosurg. 01. 2006;104(1):157-62. [pmid: 16509161].
472 Soete G, Verellen D, Tournel K, et al. Setup accuracy of stereoscopic X-ray positioning with automated correction for rotational errors in patients treated with conformal arc radiotherapy for prostate cancer. Radiother Oncol. 09. 2006;80(3):371-3. [pmid: 16914219].
473 Solberg TD, Boedeker KL, Fogg R, et al. Dynamic arc radiosurgery field shaping: a comparison with static field conformal and noncoplanar circular arcs. Int J Radiat Oncol Biol Phys. 04. 1. 2001;49(5):1481-91. [pmid: 11286857].
474 Solberg TD, Agazaryan N, Goss BW, et al. A feasibility study of 18F-fluorodeoxyglucose positron emission tomography targeting and simultaneous integrated boost for intensity-modulated radiosurgery and radiotherapy. J Neurosurg. 11. 2004;101(Suppl 3):381-9. [pmid: 15537193].
475 Solberg TD, Medin PM, Mullins J, et al. Quality assurance of immobilization and target localization systems for frameless stereotactic cranial and extracranial hypofractionated radiotherapy. Int J Radiat Oncol Biol Phys. 2008;71:S131-135. [pmid: 18406912].
476 Solberg TD, Kavanagh BD, Medin PM. Stereotactic body radiation therapy: a new paradigm in radiotherapy management of cancer. J Am Coll Radiol. 05. 2008;5(5):673-7. [pmid: 18442775].
477 Song DY, Kavanagh BD, Benedict SH, et al. Stereotactic body radiation therapy. Rationale, techniques, applications, and optimization. Oncology (Huntingt). 06. 1435;18(11):1419-30. [pmid: 15609470].
478 Sonke JJ, Rossi M, Wolthaus J, et al. Frameless stereotactic body radiotherapy for lung cancer using four-dimensional cone beam CT guidance. Int J Radiat Oncol Biol Phys. 06. 1. 2009;74(2):567-74. [pmid: 19046825].
479 Sotiropoulou E, Stathochristopoulou I, Stathopoulos K, et al. CT-guided fiducial placement for CyberKnife stereotactic radiosurgery: an initial experience. Cardiovasc Intervent Radiol. 06. 2010;33(3):586-9. Epub 2009 Nov 12. [pmid: 19908085].
480 Spadea MF, Baroni G, Riboldi M, et al. Benefits of six degrees of freedom for optically driven patient set-up correction in SBRT. Technol Cancer Res Treat. 06. 2008;7(3):187-95. [pmid: 18473490].
481 St George EJ, Kudhail J, Perks J, et al. Acute symptoms after gamma knife radiosurgery. J Neurosurg. 12. 2002;97(5 Suppl):631-4. [pmid: 12507110].
482 Stancanello J, Berna E, Cavedon C, et al. Preliminary study on the use of nonrigid registration for thoraco-abdominal radiosurgery. Med Phys. 12. 2005;32(12):3777-85. [pmid: 16475777].
483 Steinke K. Lung tumors. Recent Results Cancer Res. 2006;167:107-22. [pmid: 17044300].
484 Sterzing F, Herfarth K, Debus J. IGRT with helical tomotherapy--effort and benefit in clinical routine. Strahlenther Onkol. 12. 2007;183(Spec No 2):35-7. [pmid: 18167007].
485 Sterzing F, Schubert K, Sroka-Perez G, et al. Helical tomotherapy. Experiences of the first 150 patients in Heidelberg. Strahlenther Onkol. 01. 2008;184(1):8-14. [pmid: 18188517].
486 Storme G, Verellen D, Soete G, et al. From linac to tomotherapy: new possibilities for cure. Adv Exp Med Biol. 2006;587:303-8. [pmid: 17163173].
487 Strassmann G, Vacha P, Braun I, et al. Methodology of continuous extracranial radiosurgery for lung cancer using EXOMIO 3-D CT simulation. Strahlenther Onkol. 04. 2004;180(4):241-4. [pmid: 15057435].
488 Strassmann G, Braun I, Kress O, et al. Accuracy of single-session extracranial radiotherapy for simple shaped lung tumor or metastasis using fast 3-D CT treatment planning. Int J Radiat Oncol Biol Phys. 10. 1. 2006;66(2):576-82. [pmid: 16965999].
489 Suzuki O, Shiomi H, Nakamura S, et al. Novel correction methods as alternatives for the six-dimensional correction in CyberKnife treatment. Radiat Med. 01. 2007;25(1):31-7. [pmid: 17225051].
490 Taguchi H, Sakuhara Y, Hige S, et al. Intercepting radiotherapy using a real-time tumor-tracking radiotherapy system for highly selected patients with hepatocellular carcinoma unresectable with other modalities. Int J Radiat Oncol Biol Phys. 10. 1. 2007;69(2):376-80. [pmid: 17869660].
491 Takayama K, Nagata Y, Negoro Y, et al. Treatment planning of stereotactic radiotherapy for solitary lung tumor. Int J Radiat Oncol Biol Phys. 04. 1. 2005;61(5):1565-71. [pmid: 15817363].
492 Takeda A, Kunieda E, Shigematsu N, et al. Small lung tumors: long-scan-time CT for planning of hypofractionated stereotactic radiation therapy--initial findings. Radiology. 10. 2005;237(1):295-300. [pmid: 16118151].
493 Takeda A, Kunieda E, Takeda T, et al. Possible misinterpretation of demarcated solid patterns of radiation fibrosis on CT scans as tumor recurrence in patients receiving hypofractionated stereotactic radiotherapy for lung cancer. Int J Radiat Oncol Biol Phys. 03. 15. 2008;70(4):1057-65. [pmid: 17905527].
494 Takeda A, Kunieda E, Sanuki N, et al. Dose distribution analysis in stereotactic body radiotherapy using dynamic conformal multiple arc therapy. Int J Radiat Oncol Biol Phys. 06. 1. 2009;74(2):363-9. [pmid: 19427552].
495 Takeuchi H, Yoshida M, Kubota T, et al. Frameless stereotactic radiosurgery with mobile CT, mask immobilization and micro-multileaf collimators. Minim Invasive Neurosurg. 04. 2003;46(2):82-5. [pmid: 12761677].
496 Teh BS. Image-guided stereotactic body radiation therapy (SBRT): an emerging treatment paradigm with a new promise in radiation oncology. Biomed Imaging Interv J. 2007;3(1):e5. [pmid: 21614266].
497 Thiel DD, Winfield HN. Robotics in urology: past, present, and future. J Endourol. 04. 2008;22(4):825-30. [pmid: 18419224].
498 Theodorou K, Platoni K, Lefkopoulos D, et al. Dose-volume analysis of different stereotactic radiotherapy mono-isocentric techniques. Acta Oncol. 2000;39(2):157-63. [pmid: 10859005].
499 Theodorou K, Bazioglou M, Skouras T, et al. Linear accelerator-based stereotactic radiotherapy. Part I: rationale, techniques and future developments. J BUON. 01. 1. 2000;5(2):209-18.
500 Thieke C, Malsch U, Schlegel W, et al. Kilovoltage CT using a linac-CT scanner combination. Br J Radiol. 09. 2006;79(Spec No 1):S79-86. [pmid: 16980687].
501 Timmerman R, Papiez L, McGarry R, et al. Extracranial stereotactic radioablation: results of a phase I study in medically inoperable stage I non-small cell lung cancer. Chest. 11. 2003;124(5):1946-55. [pmid: 14605072].
502 Timmerman R, Papiez L, Suntharalingam M. Extracranial stereotactic radiation delivery: expansion of technology beyond the brain. Technol Cancer Res Treat. 04. 2003;2(2):153-60. [pmid: 12680797].
503 Timmerman R, Galvin J, Michalski J, et al. Accreditation and quality assurance for Radiation Therapy Oncology Group: Multicenter clinical trials using Stereotactic Body Radiation Therapy in lung cancer. Acta Oncol. 2006;45(7):779-86. [pmid: 16982540].
504 Timmerman R, Abdulrahman R, Kavanagh BD, et al. Lung cancer: a model for implementing stereotactic body radiation therapy into practice. Front Radiat Ther Oncol. 2007;40:368-85. [pmid: 17641520].
505 Timmerman R, Bastasch M, Saha D, et al. Optimizing dose and fractionation for stereotactic body radiation therapy. Normal tissue and tumor control effects with large dose per fraction. Front Radiat Ther Oncol. 2007;40:352-65. [pmid: 17641519].
506 Timmerman RD, Park C, Kavanagh BD. The North American experience with stereotactic body radiation therapy in non-small cell lung cancer. J Thorac Oncol. 07. 2007;2(7 Suppl 3):S101-112. [pmid: 17603304].
507 Timmerman RD, Kavanagh BD, Cho LC, et al. Stereotactic body radiation therapy in multiple organ sites. J Clin Oncol. 03. 10. 2007;25(8):947-52. [pmid: 17350943].
508 Timmerman RD, Bizekis CS, Pass HI, et al. Local surgical, ablative, and radiation treatment of metastases. CA Cancer J Clin. 05. 2009;59(3):145-70. [pmid: 19364702].
509 Tobler M, Leavitt DD, Watson G. Optimization of the primary collimator settings for fractionated IMRT stereotactic radiotherapy. Med Dosim. 2004;29(2):72-9. [pmid: 15191751].
510 Tonn JC. Microneurosurgery and radiosurgery--an attractive combination. Acta Neurochir Suppl. 2004;91:103-8. [pmid: 15707031].
511 Tsai JS, Engler MJ, Rivard MJ, et al. A formalism for independent checking of Gamma Knife dose calculations. Med Phys. 09. 2001;28(9):1842-9. [pmid: 11585215].
512 Uematsu M, Shioda A, Suda A, et al. Intrafractional tumor position stability during computed tomography (CT)-guided frameless stereotactic radiation therapy for lung or liver cancers with a fusion of CT and linear accelerator (FOCAL) unit. Int J Radiat Oncol Biol Phys. 09. 1. 2000;48(2):443-8. [pmid: 10974460].
513 Underberg RW, Lagerwaard FJ, Slotman BJ, et al. Benefit of respiration-gated stereotactic radiotherapy for stage I lung cancer: an analysis of 4DCT datasets. Int J Radiat Oncol Biol Phys. 06. 1. 2005;62(2):554-60. [pmid: 15890600].
514 Underberg RW, Lagerwaard FJ, van Tinteren H, et al. Time trends in target volumes for stage I non-small-cell lung cancer after stereotactic radiotherapy. Int J Radiat Oncol Biol Phys. 03. 15. 2006;64(4):1221-8. [pmid: 16442240].
515 Vaidya JS, Hall-Craggs M, Baum M, et al. Percutaneous minimally invasive stereotactic primary radiotherapy for breast cancer. Lancet Oncol. 04. 2002;3(4):252-3. [pmid: 12067688].
516 Van Houtte P. New potentials of radiotherapy in non-small cell lung cancer: stereotactic therapy and IMRT. Curr Probl Cancer. 01. 2003;27(1):60-3. [pmid: 12569353].
517 van der Voort van Zyp NC, Prevost JB, van der Holt B, et al. Quality of life after stereotactic radiotherapy for stage I non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 05. 1. 2010;77(1):31-7. [pmid: 19864077].
518 Varga PP, Bors I, Lazary A. Sacral tumors and management. Orthop Clin North Am. 01. 2009;40(1):105-23. [pmid: 19064059].
519 Vassiliev ON, Kry SF, Chang JY, et al. Stereotactic radiotherapy for lung cancer using a flattening filter free Clinac. J Appl Clin Med Phys. 2009;10(1):2880. [pmid: 19223837].
520 Verbakel WF, Senan S, Cuijpers JP, et al. Rapid delivery of stereotactic radiotherapy for peripheral lung tumors using volumetric intensity-modulated arcs. Radiother Oncol. 10. 2009;93(1):122-4. Epub 2009 Jun 22. [pmid: 19552979].
521 Verellen D, Soete G, Linthout N, et al. Optimal control of set-up margins and internal margins for intra- and extracranial radiotherapy using stereoscopic kilovoltage imaging. Cancer Radiother. 09. 2006;10(5):235-44. [pmid: 16854609].
522 Videtic GM, Stephans K, Reddy C, et al. Intensity-modulated radiotherapy-based stereotactic body radiotherapy for medically inoperable early-stage lung cancer: excellent local control. Int J Radiat Oncol Biol Phys. 06. 1. 2010;77(2):344-9. [pmid: 19765913].
523 Voynov G, Heron DE, Burton S, et al. Frameless stereotactic radiosurgery for recurrent head and neck carcinoma. Technol Cancer Res Treat. 10. 2006;5(5):529-35. [pmid: 16981796].
524 Vricella GJ, Ponsky LE, Cadeddu JA. Ablative technologies for urologic cancers. Urol Clin North Am. 05. 2009;36(2):163-78. [pmid: 19406318].
525 Wagner TH, Bova FJ, Friedman WA, et al. A simple and reliable index for scoring rival stereotactic radiosurgery plans. Int J Radiat Oncol Biol Phys. 11. 15. 2003;57(4):1141-9. [pmid: 14575847].
526 Wagner TH, Meeks SL, Bova FJ, et al. Optical tracking technology in stereotactic radiation therapy. Med Dosim. 2007;32(2):111-20. [pmid: 17472890].
527 Wakelee H, Langer C, Vokes E, et al. Cooperative group research efforts in lung cancer: focus on early-stage non-small-cell lung cancer. Clin Lung Cancer. 01. 2008;9(1):9-15. [pmid: 18282352].
528 Wakisaka M, Mori H, Hongo N, et al. Correlation of pathological finding with dose distribution in a case of intraocular choroidal melanoma treated by stereotactic radiosurgery. Acta Oncol. 2000;39(5):639-42. [pmid: 11093373].
529 Wallen EM. Treatment for localized prostate cancer: surgical approaches. N C Med J. 03. 2006;67(2):146-8. [pmid: 16752720].
530 Wiegner EA, King CR. Sexual function after stereotactic body radiotherapy for prostate cancer: results of a prospective clinical trial. Int J Radiat Oncol Biol Phys. 10. 1. 2010;78(2):442-8. Epub 2010 Feb 4. [pmid: 20137864].
531 Willoughby TR, Forbes AR, Buchholz D, et al. Evaluation of an infrared camera and X-ray system using implanted fiducials in patients with lung tumors for gated radiation therapy. Int J Radiat Oncol Biol Phys. 10. 1. 2006;66(2):568-75. [pmid: 16887290].
532 Wilt TJ, MacDonald R, Rutks I, et al. Systematic review: comparative effectiveness and harms of treatments for clinically localized prostate cancer. Ann Intern Med. 03. 18. 2008;148(6):435-48. [pmid: 18252677].
533 Wu QJ, Chankong V, Jitprapaikulsarn S, et al. Real-time inverse planning for Gamma Knife radiosurgery. Med Phys. 11. 2003;30(11):2988-95. [pmid: 14655946].
534 Wu QJ, Thongphiew D, Wang Z, et al. The impact of respiratory motion and treatment technique on stereotactic body radiation therapy for liver cancer. Med Phys. 04. 2008;35(4):1440-51. [pmid: 18491539].
535 Wu QJ, Wang Z, Kirkpatrick JP, et al. Impact of collimator leaf width and treatment technique on stereotactic radiosurgery and radiotherapy plans for intra- and extracranial lesions. Radiat Oncol. 2009;4. [pmid: 19159471].
536 Wulf J, Haedinger U, Oppitz U, et al. Stereotactic radiotherapy for primary lung cancer and pulmonary metastases: a noninvasive treatment approach in medically inoperable patients. Int J Radiat Oncol Biol Phys. 09. 1. 2004;60(1):186-96. [pmid: 15337555].
537 Wunderink W, Mendez RA, Vasquez Osorio EM, et al. Target coverage in image-guided stereotactic body radiotherapy of liver tumors. Int J Radiat Oncol Biol Phys. 05. 1. 2007;68(1):282-90. [pmid: 17448881].
538 Wurm RE, Gum F, Erbel S, et al. Image guided respiratory gated hypofractionated Stereotactic Body Radiation Therapy (H-SBRT) for liver and lung tumors: Initial experience. Acta Oncol. 2006;45(7):881-9. [pmid: 16982554].
539 Xiao Y, Papiez L, Paulus R, et al. Dosimetric evaluation of heterogeneity corrections for RTOG 0236: stereotactic body radiotherapy of inoperable stage I-II non-small-cell lung cancer. Int J Radiat Oncol Biol Phys. 03. 15. 2009;73(4):1235-42. [pmid: 19251095].
540 Yaeger TE. Accuray company advertising successful prostate cancer treatments with CyberKnife (CK). Int J Radiat Oncol Biol Phys. 02. 1. 2009;73(2):638-9. [pmid: 19147032].
541 Yin FF, Ryu S, Ajlouni M, et al. Image-guided procedures for intensity-modulated spinal radiosurgery. Technical note. J Neurosurg. 11. 2004;101(Suppl 3):419-24. [pmid: 15537199].
542 Yin FF, Wang Z, Yoo S, et al. Integration of cone-beam CT in stereotactic body radiation therapy. Technol Cancer Res Treat. 04. 2008;7(2):133-9. [pmid: 18345702].
543 Yousefi S, Collins BT, Reichner CA, et al. Complications of thoracic computed tomography-guided fiducial placement for the purpose of stereotactic body radiation therapy. Clin Lung Cancer. 01. 2007;8(4):252-6. [pmid: 17311689].
544 Yu C, Shepard D. Treatment planning for stereotactic radiosurgery with photon beams. Technol Cancer Res Treat. 04. 2003;2(2):93-104. [pmid: 12680789].
545 Zamzuri I, Idris NR, Mar W, et al. Early Malaysian experience on the use of head and neck localizers in the precision radiotherapy of intra and extra cranial sites for first 28 cases. Med J Malaysia. 12. 2006;61(5):621-5. [pmid: 17623965].
546 Zimmermann F, Wulf J, Lax I, et al. Stereotactic body radiation therapy for early non-small cell lung cancer. Front Radiat Ther Oncol. 2010;42:94-114. [pmid: 19955796].
547 Practice guideline for the performance of stereotactic body radiation therapy, American College of Radiology (ACR). ACR practice guideline. Reston (VA). American College of Radiology (ACR). 2006:995-1002.
548 Palacio M. Chart smart: linear accelerators. King of Prussia (PA). ADVANCE Newsmagazines/Merion Publications, Inc. 2. Also available: http://enterprise-imaging-radiology-management.advanceweb.com/sharedresources/advanceforioa/resources/DownloadableResources/AR090105_p56ChartSmart.pdf.
549 Direx Systems. 510(k) summary. AccuChanger. K043409. Rockville (MD). U.S. Food and Drug Administration (FDA). 05. 5. 2005:6. Also available: http://www.fda.gov/cdrh/pdf4/K043409.pdf.
550 Direx Systems. 510(k) summary for AccuLeaf. K040553. Rockville (MD). U.S. Food and Drug Administration (FDA). 04. 1. 2004:5. Also available: http://www.fda.gov/cdrh/pdf4/K040553.pdf.
551 Elekta Limited. Summary of safety and effectiveness for the beam modulator. K042794. Rockville (MD). U.S. Food and Drug Administration (FDA). 01. 31. 2005:5. Also available: http://www.fda.gov/cdrh/pdf4/K042794.pdf.
552 Accuray. 510(k) summary of safety and effectiveness for CyberKnife® Robotic Radiosurgery System. K072504. Rockville (MD). U.S. Food and Drug Administration (FDA). 09. 4. 2007:4. Also available: http://www.fda.gov/cdrh/pdf7/K072504.pdf.
553 Elekta Limited. 510(K) summary. Medical linear accelerator accessory, lYE. K082122. Rockville (MD). U.S. Food and Drug Administration (FDA). 07. 18. 2008:4. Also available: http://www.fda.gov/cdrh/pdf8/K082122.pdf.
554 Varian Medical Systems. 510(k) summary. Medical charged particle radiation therapy system. K071992. Rockville (MD). U.S. Food and Drug Administration (FDA). 08. 15. 2007:5. Also available: http://www.fda.gov/cdrh/pdf7/K071992.pdf.
555 Elekta Instrument AB. 510(k) summary. Radionuclide radiation therapy system. K063512. Rockville (MD). U.S. Food and Drug Administration (FDA). 03. 5. 2007:5. Also available: http://www.fda.gov/cdrh/pdf6/K063512.pdf.
556 BrainLAB AG. 510(k) summary of safety and effectiveness for m3 (micro-Multileaf Collimator). K020860. Rockville (MD). U.S. Food and Drug Administration (FDA). 06. 2002:5. Also available: http://www.fda.gov/cdrh/pdf2/K020860.pdf.
557 Mitsubishi Heavy Industries, Ltd. 510(k) premarket notification database. Accelerator, linear, medical. K072047. [internet]. Rockville (MD). U.S. Food and Drug Administration (FDA). 11. 10. accessed 2008 Nov 24. 2008:1. Available: http://www.accessdata.fda.gov/scrIpts/cdrh/cfdocs/cfPMN/pmn.cfm?ID=25401.
558 Siemens Medical Solutions USA. 510(k) summary for the microMLC. K032790. Rockville (MD). U.S. Food and Drug Administration (FDA). 10. 2. 2003:5. Also available: http://www.fda.gov/cdrh/pdf3/K032790.pdf.
559 MRC Systems GmbH. 510(k) summary of safety and effectiveness for multileaf collimator. K030609. Rockville (MD). U.S. Food and Drug Administration (FDA). 02. 21. 2003:5. Also available: http://www.fda.gov/cdrh/pdf3/K030609.pdf.
560 Varian Medical Systems. 510(k) summary for the medical charged particle radiation therapy system. K081188. Rockville (MD). U.S. Food and Drug Administration (FDA). 07. 14. 2008:4. Also available: http://www.fda.gov/cdrh/pdf8/K081188.pdf.
561 BrainLAB AG. 510(k) summary of safety and effectiveness for ExacTrac 3rd party. K072046. Rockville (MD). U.S. Food and Drug Administration (FDA). 10. 17. 2007:5. Also available: http://www.fda.gov/cdrh/pdf7/K072046.pdf.
562 Varian Medical Systems. 510(k) summary for imaging accessory to medical linear accelerator. K042720. Rockville (MD). U.S. Food and Drug Administration (FDA). 10. 29. 2004:4. Also available: http://www.fda.gov/cdrh/pdf4/K042720.pdf.
563 Siemens Medical Solutions USA. 510(k) summary for ONCOR Avant-Garde with COHERENCE workspaces. K031764. Rockville (MD). U.S. Food and Drug Administration (FDA). 09. 5. 2003:6. Also available: http://www.fda.gov/cdrh/pdf3/K031764.pdf.
564 Siemens Medical Solutions USA. 510(k) summary for ONCOR Expression TM with COHERENCETM Workspaces. K06226. Rockville (MD). U.S. Food and Drug Administration (FDA). 03. 15. 2006:7. Also available: http://www.fda.gov/cdrh/pdf6/K060226.pdf.
565 Siemens Medical Solutions USA, Inc. 510(k) summary and statement for ARTISTE MV SA. K072485. Rockville (MD). U.S. Food and Drug Administration (FDA). 12. 27. 2007:4. Also available: http://www.fda.gov/cdrh/pdf7/K072485.pdf.
566 Elekta Limited. 510(k) summary. Medical linear accelerator (with patient imaging). K051932. Rockville (MD). U.S. Food and Drug Administration (FDA). 08. 12. 2005:5. Also available: http://www.fda.gov/cdrh/pdf5/K051932.pdf.
567 TomoTherapy. 510(k) safety and effectiveness summary. Medical charged particle radiation therapy. K082005. Rockville (MD). U.S. Food and Drug Administration (FDA). 07. 7. 2008:5. Also available: http://www.fda.gov/cdrh/pdf8/K082005.pdf.
568 TomoTherapy. Summary of safety and effectiveness. Radiation therapy system. K060912. Rockville (MD):. U.S. Food and Drug Administration (FDA). 04. 19. 2006:6. Also available: http://www.fda.gov/cdrh/pdf6/K060912.pdf.
569 TomoTherapy. Safety and effectiveness summary. Radiation therapy system. K042739. Rockville (MD). U.S. Food and Drug Administration (FDA). 11. 3. 2004:6. Also available: http://www.fda.gov/cdrh/pdf4/K042739.pdf.
570 TomoTherapy. 510(k) safety and effectiveness summary. Radiation therapy system. K013673. Rockville (MD). U.S. Food and Drug Administration (FDA). 11. 3. 2001:6. Also available: http://www.fda.gov/cdrh/pdf/K013673.pdf.
571 Radionics Software Applications. 510 (k) summary of safety and effectiveness. Mini multi-leaf collimator (MMLC VR1). K993594. Rockville (MD). U.S. Food and Drug Administration (FDA). 12. 15. 1999:4. Also available: http://www.fda.gov/cdrh/pdf/K993594.pdf.
572 Accuray CyberKnife stereotactic radiosurgery system. [Web site]. Sunnyvale (CA). Accuray, Inc. 2006. accessed 2006 Feb 15. [various]. Available: http://www.accuray.com.
573 BrainLAB AG. [Web site]. Westchester (IL). BrainLAB AG. accessed 2008 Nov 21. [various]. Available: http://www.brainlab.com/scripts/website_english.asp.
574 Direx Group. [Web site]. Canton (MA). Direx Systems Corp. accessed 2008 Nov 21. [various]. Available: http://www.direxgroup.com.
575 Elekta AB. [Web site]. Stockholm, Sweden. Elekta AB (Publ). accessed 2008 Nov 21. [various]. Available: http://www.elekta.com.
576 Mitsubishi Heavy Industries, Ltd. [Web site]. Tokyo. Mitsubishi Heavy Industries, Ltd. (MHI). accessed 2008 Nov 21. [various]. Available: http://www.mhi.co.jp/en/index.html.
577 Integra Radionics. [Web site]. Burlington (MA). Integra Radionics. accessed 2008 Nov 21. [various]. Available: http://www.radionics.com.
578 Company profile: Siemens Medical Systems, Inc. [internet]. Iselin (NJ). Siemens Medical Systems, Inc. accessed 1999 Jul 12. 2. Available: http://www.usa.siemens.com/About_Siemens/OperatingCompanies/SiemensMedicalSys.htm.
579 TomoTherapy. [Web site]. Madison (WI). TomoTherapy Incorporated. accessed 2008 Nov 21. [various]. Available: http://www.tomotherapy.com.
580 Varian Medical Systems [Web site]. Palo Alto (CA). Varian Medical Systems, Inc. accessed 2008 Nov 21. [various]. Available: http://www.varian.com.
581 Hahn E. Elekta, Inc. Personal communication. 01. 6. 2010:7.
582 Hedgspeth L. Tomotherapy, Inc. Madison, WI. Personal communication. 01. 11. 2010:5.
583 Thomes CJ. Director Corporate Accounts, Accuray Incorporated. Personal communication. 01. 6. 2010:10.
584 Berkowitz D, Huntzinger C, Schulz R. Varian Surgical Sciences, Palo Alto CA. Personal communication. 01. 15. 2010:10.
585 Benedict SH. SBRT: technical issues for clinical implementation of an SBRT program. 23rd annual meeting of the American Academy of Pain Medicine. February 7–10, 2007. New Orleans, LA. Glenview (IL). American Academy of Pain Medicine (AAPM). 2007. Also available: http://aapm.confex.com/aapm/2007am/techprogram/S1237.HTM.