# Responses From Device Manufacturers on Device Specifications and Compatible Accessories (January 2010)

| Elekta Axesse581 | Elekta Synergy-S581 | Elekta Synergy581 | Elekta Infinity581 | Tomo- Therapy- HiArt582 | Accuray CyberKnife® Robotic Radiosurgery System583 | Varian Clinac iX584 | Varian Trilogy584 | Varian/BrainLAB Novalis Tx584
Device Type (e.g., robot, ring gantry, standard linac) | Standard linac and robotic table | Standard linac and robotic table | Standard linac and robotic table | Standard linac and optional robotic table | Ring gantry | Robotic mounted linac | C-Arm Linac | C-Arm Linac | C-Arm Linac
Photon Energy, MV | 6, 10, 12, or 15 MV | 6, 10, 12, or 15 MV | 6, 10, 12, 15, or 18 MV | 6, 10, 12, 15, or 18 MV | 6 MV | 6 MV | 6 MV plus one of 10,15,18,20 HighX | 6 MV plus one of 10,15,18,20 HighX | 6 MV plus one of 10, 15, 18, 20 HighX
Maximum Dose Rate (MU/min) | 600 MU/min | 600 MU/min | 600 MU/min | 600 MU/min | 850 cGy/min | 1,000 MU/min | 600 MU/min^1^ | 1,000 MU/min^1^ | 1,000 MU/min^1^
Number of Independent Beam Angles | Infinite^2^ | Infinite^2^ | Infinite^2^ | Infinite^2^ | 51 per rotation, continuous delivery modeled by treatment (7 degree arcs) | >1,200 noncoplanar, independent beam angles | Continuously variable along gantry, collimator & couch rotational axes plus couch & collimator translational axes^3^ | Continuously variable along gantry, collimator & couch rotational axes plus couch & collimator translational axes^3^ | Continuously variable along gantry, collimator & couch rotational axes plus couch & collimator translational axes^3^
Collimation Technique (e.g., MLC, etc.) | MLC or cones | MLC or cones | Add-on MLC or cones | Add-on MLC or cones | MLC | Variable aperture collimator and fixed circular collimator^4^ | MLC^5^ | MLC^5^ | MLC and SRS cones^6^
Smallest Collimation Resolution | 4 mm throughout or cones^7^ | 4 mm throughout or cones^7^ | 3 mm or 2.5 mm throughout or cones^7^ | 3 mm or 2.5 mm throughout or cones^7^ | 6.25 mm × 10 mm | Field sizes of 5 mm^8^ | 5.0 mm | 5.0 mm | 2.5 mm
Minimum Treatment Size | MLC: 4 mm | MLC: 4 mm | MLC: 3 mm or 2.5 mm | MLC: 3 mm or 2.5 mm | Not limited by collimator | 5 mm^8^ | MLC: 5 mm × 5 mm SRS cone: 4 mm | MLC: 5 mm × 5 mm SRS cone: 4 mm | MLC: 2.5 mm × 2.5 mm SRS cone: 4 mm
Maximum Treatment Size | MLC: 16 cm × 21 cm | MLC: 16 cm × 21 cm | MLC: 7 cm × 7 cm or 12 cm × 12 cm | MLC: 7 cm × 7 cm or 12 cm × 12 cm | NR | Conformal beam targeting allows treatment of tumors >maximum field size of 60 mm | Fixed field: 40 cm × 40 cm Modulated field: 40 cm × 32 cm | Fixed field: 40 cm × 40 cm Modulated field: 40 cm × 32 cm | Fixed field: 22 cm × 40 cm Modulated field: 22 cm × 32 cm
Body Immobilization Technique (e.g., third party) | BodyFIX or HeadFIX | BodyFIX or HeadFIX | BodyFIX or HeadFIX | BodyFIX or HeadFIX | BodyFIX^9^ | Not required, optional “vac-bags”^9^ | Medical Intelligence CIVCO; Q-Fix; Aktina^9^ | Medical Intelligence CIVCO; Q-Fix; Aktina^9^ | Medical Intelligence; CIVCO; Q-Fix; Aktina^9^
Treatment Planning Imaging (e.g., CT, PET-CT, MRI, etc.) | CT and/or MRI and/or PET | CT and/or MRI and/or PET | CT and/or MRI and/or PET | CT and/or MRI and/or PET | CT on HiArt planning station, multi- modality on third party fusion/contouring station | CT, 4D CT, MR, PET, and XA (3DRA) | CT, MR, PET, CT/PET | CT, MR, PET, CT/PET | CT, MR, PET, CT/PET
Treatment Planning Options (e.g., software) | ERGO++ and/or Pinnacle3^9^ | ERGO++ and/or Pinnacle3^9^ | ERGO++ and/or Pinnacle3^9^ | ERGO++ and/or Pinnacle3^9^ | Tomo- Helical and Tomo- Direct delivery mode, each with IMRT and 3D options | The MultiPlan® Treatment Planning System | Varian Eclipse recommended | Varian Eclipse recommended | BrainLAB iPlan Standard; Varian Eclipse recommended in addition
Treatment Planning Algorithm (e.g., Monte Carlo, forward, inverse) | Inverse and/or Monte Carlo | Inverse and/or Monte Carlo | Inverse and/or Monte Carlo | Inverse and/or Monte Carlo | Convolution/super- position | Inverse planning with Monte Carlo or ray-tracing methods | Eclipse: AAA and Pencil Beam | Eclipse: AAA and Pencil Beam | Varian Eclipse: AAA and Pencil Beam, BrainLAB iPlan: Pencil Beam and Monte Carlo
Patient Positioning Accuracy (mm) | <1 mm | <1 mm | <1 mm | <1 mm | Approx 0.5 mm | During set-up: 1 mm | Follows AAPM and ASTRO recommendations^10^ | Follows AAPM and ASTRO recommendations^10^ | Follows AAPM and ASTRO recommendations^10^
Patient Position Correction (degrees of freedom) | 6D standard | 3D standard, optional 6D | 3D standard, optional 6D | 3D standard, optional 6D | Translation plus roll | RoboCouch® System provides 6-DOF motion capabilities | 4 | 4 | 6
Image Guided Technology (during treatment) | 2D or 3D cone-beam CT | 2D or 3D cone-beam CT | 2D or 3D cone- beam CT | 2D or 3D cone- beam CT | MVCT prior to delivery | Orthogonal X-ray (kV), registers to DRRs | Varian Cone- Beam CT; MV Portal Imaging; Fluoro kV, MV/kV | Varian Cone-Beam CT; MV Portal Imaging; Fluoro kV, MV/kV | Varian Cone-Beam CT; MV Portal Imaging; Fluoro kV, MV/kV, BrainLAB, ExacTrac Stereo X-Ray, ExacTrac Optical (IR), SNAP (kV image w/beam on)
Tumor Tracking (e.g., fiducials, third party, manufacturer) | Active Breathing Coordinator (ABC) and/or Elekta Symmetry 4D cone-beam CT | ABC and/or Elekta Symmetry 4D cone-beam CT | ABC and/or Elekta Symmetry 4D cone-beam CT | ABC and/or Elekta Symmetry 4D cone-beam CT | No tracking during treatment | Xsight Lung Tracking System and fiducial-based tracking | Varian Fluoro kV and via Calypso or VisionRT^9^ | Varian Fluoro kV and via Calypso or VisionRT^9^ | Varian Fluoro kV and via BrainLAB SNAP (kV image w/beam on) and Calypso or VisionRT^9^
Respiratory Gating (Yes/No) | Yes, ABC | Yes, ABC | Yes, ABC | Yes, ABC | No | No—Uses Synchrony® Respiratory Tracking System | Varian RPM: Respiratory Position Management | Varian RPM: Respiratory Position Management | Varian RPM: Respiratory Position Management BrainLAB: Adaptive Gating
Standard Treatment Time Per Fraction 11 | 2–45 mins (lower with VMAT, higher with SRS) | 2–45 mins (lower with VMAT, higher with SRS) | 2–45 mins (lower with VMAT, higher with SRS) | 2–45 mins (lower with VMAT, higher with SRS) | Typically beam on 20 minutes and time in room 45 minutes | Avg. 30–60 min per fraction imaging interval and tracking method used | 5–35^12^ | 3–20^12^ | 3–20^12^

1 Varian states the dose rate is at 100 centimeters (cm).

2 Based on rotation of linac and control of patient table.

3 Varian states: linacs rotate continuously + 185 degrees (370 degrees total) about the isocenter from vertical; the couch can yaw + 100 degrees; rotate the multileaf collimator + 165 (+ 0.5 degrees); the leaf positions are continuously variable with a + 0.01 mm leaf position resolution; Exact Couch has a lateral travel of + 25 cm and a longitudinal travel of 145.8 cm; BrainLAB’s robotic couch top, standard on the Novalis Tx (and optional on the Trilogy and Clinac iX), can roll and pitch + 2.7 degrees and + 4 degrees respectively.

4 5–60 mm diameter.

5 Millennium 120 MLC: 80-5 mm leafs bounded by 40 (2 × 20) 10 mm leafs.

6 HD120 MLC: 64 2.5 mm leafs bounded by 56 (2 × 28) 5 mm leafs.

7 2.5 mm to 50 mm.

8 This represents the smallest collimator size; Accuray states collimator resolution is not applicable for the CyberKnife system.

9 Third party device or software.

10 Varian states they follow recommendations of AAPM and ASTRO585

11 Standard treatment time may vary with each patient depending on factors such as tumor size, etc.

12 Varian based the treatment time on a treatment dose range of 8–20 Gy and delivery using RapidArc or Fixed Gantry.

4D CT: Four-dimensional computed tomography

AAA: Anisotropic analytical algorithm

AAPM: American Association of Physicists in Medicine

ABC: Active Breathing Coordinator

ASTRO: American Society for Radiation Oncology

cGY/min:Centigray per minute

cm: Centimeter

CT: Computed tomography

DOF: Degrees of freedom

DRR: Digitally reconstructed radiograph

IMRT: Intensity modulated radiation therapy

kV: Kilovolt

MLC: Multi-leaf collimator

mm: Millimeter

MRI: Magnetic resonance imaging

MU/min: Monitor units per minute

MV: Megavolt

MVCT: Megavoltage computed tomography

PET: Positron emission tomography

SRS: Stereotactic radiosurgery

VMAT: Volumetric modulated arc therapy