# Literature Results Device Specifications

Study | Device and Photon Energy | Beam Angles | Collimation Technique | Body Immobilization Technique | Treatment Planning Imaging | Treatment Planning System/Algorithm | Tumor Tracking | Respiratory Tracking/Control | Imaging Guidance During Treatment
Freeman et al. (2011)23 | Cyberknife 6 MV | 150–200 noncoplanar beams | NS | NS | CT, MRI | NS | Fiducial markers (3–4) | NS | Orthogonal x-ray images
Aluwini et al. (2010)3 | Cyberknife | NS | NS | NS | CT, MRI | NS | NS | NS | NS
Bolzicco et al. (2010)8 | Cyberknife 6 MV | Noncoplanar | NS | NS | CT | Non-isocentric inverse treatment planning | 4 Fiducials | NS | Orthogonal x-ray images
Bradley et al. (2010)9 | NS | 8–11 beams | NS | SBF, BodyFix, Alpha Cradle | 4D CT | Tissue heterogeneity corrections | NS | NS | NS
Cardenes et al. (2010)11 | Linac 6MV | 7–12 non-opposing, noncoplanar fields | NS | SBF | CT | NS | NS | NS | Cone-beam computed tomography
Crabtree et al. (2010)19 | Trilogy | 10–12 noncoplanar beams | NS | NS | NS | NS | Fiducials | NS | NS
Dunlap et al. (2010)21 | Hi-Art Tomotherapy | NS | NS | Stereotactic frame | CT | Inverse planning software (Tomotherapy) and BrainScan planning software (BrainLab) | Fiducial markers | NS | NS
Goodman et al. (2010)27 | Cyberknife | NS | NS | Alpha Cradle | CT, PET | Multiplan (Accuray) | Fiducials (3–5) 5mm × 1mm | Synchrony | NS
Grills et al. (2010)28 | NS | 6–9 coplanar and noncoplanar beams | NS | SBF or Alpha cradle | 4D CT, PET | Pinnacle | NS | NS | Cone-beam computed tomography
Guckenberger et al. (2010)31 | NS | NS | NS | SBF or BodyFix system | CT, cone- beam CT | NS | NS | NS | Verification imaging
Hamamoto et al. (2010)34 | Linac 4 MV | 8–11 noncoplanar static beams | mMLC | BodyFix | CT | 3D treatment planning (BrainSCAN)/pencil beam algorithm | NS | NS | NS
Jorcano et al. (2010)46 | Novalis 6 MV | NS | mMLC | Customized vacuum body cast | CT, MRI | NS | Infrared (IR) reflecting metallic markers | NS | Infrared cameras
Kang et al. (2010)48 | Cyberknife | NS | NS | Alpha cradle | CT, MRI, PET | NS | NS | 4 belts to compress abdomen | NS
Kim et al. (2010)53 | Cyberknife | NS | NS | Customized thermoplastic mask and vacuum cushion | Contrast- enhanced CT | On-target Planning System | NS | NS | Orthogonal x-ray images
Kopek et al. (2010)55 | Seimens Primus | 5–8 static coplanar or noncoplanar beams | MLC with leaf width 5 or 10 mm at isocenter | Customized vacuum pillow fixed in SBF (Elekta) | CT | Helax-TMS (MDS- Nordion, Freiburg, Germany) treatment planning system | NS | Abdominal compression | CT scan first treatment day; portal imaging with matching to vertebral column
Louis et al. (2010)62 | Cyberknife | NS | NS | Vacuum mattress or self-expanding foam mattress | CT | Multiplan (Accuray) | Fiducials (2–6) 0.88 mm × 5 mm | Synchrony | NS
Mahadevan et al. (2010)64 | CyberKnife 6MV | NS | NS | Memory foam placed over customized Vac- Lok (CIVCO Medical Solutions) immobilization cradle | CT | MultiPlan workstation (Accuray) | Fiducials (3–5) 5 mm × 0.8 mm | Synchrony | NS
Oermann et al. (2010)74 | Cyberknife | NS | NS | NS | CT, MRI | Multiplan (Accuray) | At least 4 gold fiducials | NS | NS
Polistina et al. (2010)80 | CyberKnife 6MV | Noncoplanar | NS | Alpha cradle immobilization device; vacuum preconformed bed | CT | NS | Fiducial markers 3 or more | Synchrony | NS
Seo et al. (2010)91 | Cyberknife | NS | NS | Alpha Cradle | CT, MRI, PET | NS | Fiducials (6) 4 mm × 0.8 mm | 4 belts to compress abdomen | Orthogonal x-ray images
Shin et al. (2010)93 | Cyberknife | NS | 20, 25, 30, 35, 40 mm diameter circular collimator | Alpha cradle | CT, MRI, PET | Pencil beams | Fiducials (6) 4 mm × 0.8 mm | 4 belts to compress abdomen | NS
Son et al. (2010)96 | CyberKnife 6MV | NS | NS | NS | NS | NS | Skin markers | Abdominal compression, breath hold | NS
Stintzing et al. (2010)102 | Cyberknife 6 MV | NS | NS | NS | CT, MRI | NS | Gold fiducials 5 mm × 0.5 mm | NS | Orthogonal x-ray images
Stintzing et al. (2010)101 | Cyberknife 6 MV | NS | NS | NS | CT, MRI | NS | Fiducials (1–2) 5 mm × 0.5 mm | NS | Orthogonal x-ray images
Takeda et al. (2010)106 | NS | NS | NS | NS | CT | Superposition algorithm | NS | NS | NS
Timmerman et al. (2010)109 | Linac | NS | NS | NS | CT | No tissue density heterogeneity correction was allowed | NS | Abdominal compression, gating, breath hold | 4D CT scans, fluoroscopy
Townsend et al. (2010)110 | CyberKnife 6MV | NS | NS | Custom-fit body mold | CT | Inverse planning technique | Fiducial markers | NS | NS
Trovo et al. (2010)111 | Trilogy 6 MV | Multiple coplanar and noncoplanar beams | NS | SBF or BodyFix | CT | Superposition/convolution algorithm | NS | NS | NS
Unger et al. (2010)114 | Cyberknife | NS | NS | NS | CT | Nonisocentric, inverse-planning algorithm with tissue density heterogeneity | Fiducials (3–5) 0.8–1 mm × 3–7 mm | Form fitting vest with 3 red light emitting surface markers | Orthogonal x-ray images
Vahdat et al. (2010)115 | CyberKnife 6MV | Hundreds of beams | Single collimator 20–30 mm in diameter | NS | CT | Nonisocentric inverse planning algorithm with tissue heterogeneity corrections | Fiducials; 3 LEDs placed on patients anterior torso | NS | Orthogonal x-ray images; live camera array signal and correlation model
Yamashita et al. (2010)121 | Synergy | At least 8 beams | NS | Body frame | CT | 3D treatment planning machine (Pinnacle3) | NS | Abdominal pressure board | NS
Yang et al. (2010)122 | Body GammaKnife | NS | NS | Vacuum cushion | CT | 3D treatment planning system | NS | NS | NS
Hof et al. (2009)40 | Linac 6 MeV | 6–7 isocentric portals | NS | Vacuum pillow inside stereotactic frame | CT | 3D treatment planning VIR-TUOS software (German Cancer research center)/pencil beam algorithm dose calculation | NS | NS | NS
Ahn et al. (2009)2 | CyberKnife 6MV | NS | NS | NS | NS | NS | NS | NS | NS
Chawla et al. (2009)14 | Novalis | Conformal arcs | NS | NS | CT, PET | BrainLAB 3D Brain SCAN system | NS | Breath hold technique | ExacTrac
Choi et al. (2009)16 | CyberKnife 6MV | NS | NS | Alpha Cradle and four belts to restrict respiratory motion (Smithers Medical) | CT | CyberKnife planning system | Six 4 mm length × 0.8 mm diameter fiducials | NS | NS
Collins et al. (2009)17 | CyberKnife 6MV | NS | NS | NS | CT | Nonisocentric inverse plan | 3–5 gold fiducials 0.8–1 mm (diameter) × 3–7 mm (length) | NS | Light emitting diodes (LEDs) on patients anterior torso; Orthogonal x- ray imagers
Guckenberger et al. (2009)30 | Linac | NS | NS | SBF (Elekta); BodyFix system (Medical Intelligence) | CT | NS | NS | Abdominal compression | Out of room CT scanner, in-room single slice CT scanner; integrated cone-beam CT (Elekta)
Haasbeek et al. (2009)33 | Linac | 8–11 radiation beams | NS | NS | 4D CT | BrainLAB BrainScan version 5.31 treatment planning software and Philips medical Systems Pinnacle Treatment Planning System | NS | NS | Orthogonal x-ray images or conebeam CT
Kopek et al. (2009)54 | Siemens Primus or Varian Clinac 2100/2300 6 or 8MV | 5–8 static coplanar or noncoplanar beams | MLC leaf width 5–1 mm at isocenter | SBF (Elekta) | CT | MDS Nordion Helax TMS or Varian CadPlan Plus/Eclipse treatment-planning systems/pencil beam algorithm dose calculation with heterogeneity correction | NS | Diaphragmatic compression | Portal field imaging and CT scan
Kawase et al. (2009)50 | Linac | NS | NS | NS | CT | Koninklijke Philips Electronics Pinnacle3 planning system or CMS Xio | NS | NS | NS
Kim et al. (2009)52 | CyberKnife 6 MV | NS | Single 20, 25, or 30 mm diameter collimator | Alpha Cradle (Smithers Medical) | CT | CyberKnife planning system/pencil beam | 6 gold fiducials 4 mm (long) × 0.8 mm (diameter) | 4 belts to compress the abdomen | NS
King et al. (2009)305 | CyberKnife 6 MV | NS | NS | Alpha cradle | CT | NS | 3 gold fiducials | NS | Image guidance
Milano et al. (2009)68 | Novalis | NS | NS | NS | NS | BrainScan system | NS | Breath hold technique or shallow breathing | ExacTrac
Milano et al. (2009)66 | Linac | Conformal arcs | NS | | CT, PET | BrainLAB BrainScan treatment planning system | NS | NS | ExacTrac
Milano et al. (2009)67 | Novalis | Conformal arcs or multiple fixed coplanar beams | NS | Vacuum bag | CT | BrainLAB BrainScan treatment planning system | NS | NS | ExacTrac
Lee et al. (2009)61 | Linac | NS | NS | Customized body mold | CT, MRI | NS | NS | Elekta ABC or abdominal compression | 2D orthogonal MV image guidance; 3D kV cone beam CT combined with 2D kV fluoroscopy
Olsen et al. (2009)75 | Linac | NS | NS | NS | NS | NS | NS | Assisted breathing device or abdominal compression plate | NS
Pennathur et al. (2009)79 | Linac | NS | NS | Alpha Cradle (Smithers Medical) | CT | NS | 1–4 fiducials implanted | Breath hold, Synchrony | Rea- time image guidance
Ricardi et al. (2009)83 | Elekta Precise linac 6 and 10 MV | 6–8 static nonopposing, noncoplanar | NS | Vacuum pillow and SBF (Elekta) | CT | OTP version 1.5 software for treatment planning Nucletron/collapsed cone algorithm dose calculation | NS | Abdominal compression devices | Orthogonal electronic portal images, DRRs
Seong et al. (2009)92 | CyberKnife 6 MV | NS | NS | NS | NS | NS | NS | NS | NS
Rusthoven et al. (2009)85 | Linac | NS | NS | NS | NS | NS | NS | NS | NS
Rusthoven et al. (2009)86 | Linac 6–15 MV | Dynamic conformal arcs or multiple noncoplanar static beams >7 noncoplanar fields | NS | External vacuum type or synthetic body mold | CT | NS | Fiducial markers on body immobilization or infrared markers on patients surface | ABC or abdominal compression | Orthogonal x-rays or onboard CT imaging
Rusthoven et al. (2009)87 | Linac 6–15 MV | Dynamic conformal arcs or multiple noncoplanar static beams | NS | External vacuum type; synthetic body mold; or abdominal compression | CT | NS | NS | Facilitated breath hold or abdominal compression | Orthogonal x-rays or onboard CT imaging
Song et al. (2009)98 | Linac | Median: 6 (Range: 4–8) coplanar or noncoplanar beams | NS | SBF, vacuum fitted (Elekta) | CT | Elekta Render 3D planning system or Varian Eclipse planning system | NS | ABC, abdominal compression, or respiratory gated therapy (Varian and GE Lightspeed) | Cone-beam or CT simulation; on-board imager with cone beam CT
Stephans et al. (2009)100 | Novalis 6MV | 7 field noncoplanar IMRT with heterogeneity corrections or 3 or more dynamic arcs without heterogeneity corrections | NS | BodyFix vacuum bag | CT | BrainScan 5.31 planning software | NS | Abdominal compression | Orthogonal films and Exactrac
Stephans et al. (2009)99 | Novalis | NS | NS | BodyFix (Elekta) | CT | BrainLAB BrainScan 5.31 planning software | NS | Abdominal compression device | ExacTrac, Orthogonal films
van der Voort van Zyp et al. (2009)116 | CyberKnife 6MV | 130 noncoplanar beams | 1 or 2 circular collimator cone sizes 20–60 mm | NS | CT | Accuray version 3.4.1 on target treatment-planning system | Minimum of 3 implanted markers | Synchrony | Orthogonal X-ray images
Baumann et al. (2008)6 | Linac 6MV | 5–9 noncoplanar or coplanar beams | MLC | SBF (Elekta) | CT | Helax TMS or Eclipse systems/pencil beam algorithms with heterogeneity correction | NS | Abdominal compression | CT scan before treatment
Casamassima et al. (2008)12 | Elekta Synergy 6 MV | Dynamic arc technique; arc interval in the transverse plane minimum of 180 to 270, subarcs of 30; non coplanar arcs were used in some patients | MLC | SBF | CT | Treatment planning system ERGO 3D line/pencil beam algorithm dose calculation | NS | NS | Cone-beam CT for online setup corrections
Chang et al. (2008)1 | CyberKnife 6MV | 6 degrees of freedom | NS | Alpha Cradle (Smithers Medical) | CT, PET | NS | 3–5 implanted fiducials | Synchrony | Orthogonal x-ray sources & amorphous silicon detectors
Chang et al. (2008)13 | Linac 6MV | 6–9 noncoplanar beams | NS | NS | CT | NS | NS | NS | CT on-rail simulation during each treatment fraction; orthogonal films
Choi et al. (2008)15 | CyberKnife 6MV | NS | NS | NS | CT | NS | 4 gold markers | Breath hold | NS
Coon et al. (2008)18 | CyberKnife 6MV | 6 axis robotic arm | NS | NS | PET, CT | Non isocentric inverse planning algorithm | 1–4 gold fiducial markers | Synchrony | Orthogonal x-rays
Fritz et al. (2008)24 | Elekta Precise Sli linac | 5–8 coplanar fields planned | MLC leaf width 10 mm | SBF (Elekta) | 4D CT | Eclipse 3D planning system version 7.3.10/pencil beam algorithm dose planning with heterogeneity correction | NS | NS | CT immediately before treatment
Fuller et al. (2008)25 | CyberKnife 6MV | NS | NS | NS | CT, MRI | NS | Implanted gold fiducial markers | NS | NS
Henderson et al. (2008)36 | Linac 6 and 15MV | 7–10 noncoplanar compensated beams | NS | SBF and vacuum pillow (Elekta) | CT | NS | Prepatellar and sterna positioning marks | Abdominal pressure device | NS
Jereczek- Fossa et al. (2008)45 | Linac 6–18 MV | 1–3 noncoplanar conformal dynamic arc | mMLC | Vacuum pillow fixed on a carbon fiber tray | CT, PET, MRI | BrainLAB BrainScan treatment planning v 5.31 | NS | NS | ExacTrac
Katoh et al. (2008)49 | Linac | NS | MLC | No immobilization | CT | NS | Implanted 2 mm gold marker | Synchrony | 4 fluoroscopy image processor units
Kim et al. (2008)51 | CyberKnife 6MV | NS | NS | Alpha Cradle (Smithers Medical) | CT, PET | CyberKnife planning system | 6 gold fiducials 4 mm (long) × 0.8 mm (diameter) | NS | NS
Kunos et al. (2008)57 | CyberKnife 6MV | NS | NS | Vacuum bag pelvic | CT | Accuray inverse treatment planning system | 6 single 1.6 × 3 mm gold soft tissue markers | NS | Cross plane radiographic imaging
Lagerwaard et al. (2008)58 | Linac | 8–12 noncoplanar static beams | mMLC | NS | 4D CT | BrainLAB BrainScan v 5.2 | NS | NS | Varian real-time position management system
McCammon et al. (2008)65 | Conventional linac and Novalis dedicated linac 6MV | Single or multiple dynamic conformal arcs or multiple noncoplanar static beams | MLC | Vac-Lok, MedTec OR Alpha Cradle (Smithers Medical) | CT, PET, MRI | BrainLAB BrainScan software/pencil-beam algorithm for tissue inhomogeneity correction | Fiducial skin markers | Elekta ABC, abdominal compression | ExacTrac, CT scan, or stereoscopic image guidance
Onimaru et al. (2008)76 | Linac 4, 6, and 10MV | NS | NS | NS | CT | CMS Focus or Xio planning systems | Gold markers | Breath hold | NS
Norihisa et al. (2008)71 | Linac 6MV | 5–7 noncoplanar static beams | MLC | SBF (Elekta) | CT | Varian CADPLAN version 3.1 and Eclipse version 7.1 | NS | NS | NS
Salazar et al. (2008)88 | Linac | 3–9 fields | MLC | SBF | CT, PET | NS | External fiducial markers on immobilization device | ABC mask | NS
Schellenberg et al. (2008)89 | CyberKnife 6MV | NS | NS | Alpha cradle | CT, PET | CyberKnife planning system | Implanted gold fiducial seeds | Respiratory gating, Synchrony | NS
Svedman et al. (2008)104 | Linac 6 MV | 5–8 coplanar or noncoplanar static beams | MLC | SBF | CT | Helix TMS planning system/pencil beam algorithm dose calculation | NS | Abdominal pressure device | NS
Takeda et al. (2008)105 | Linac | 10 dynamic conformal arcs with or without additional static conformal ports | NS | NS | CT | CMS XiO version 4.2 or 4.3 3D treatment- planning system/MG-superposition algorithm dose calculation with heterogeneity correction | NS | Long scan time CT to account for breathing motion | NS
Tse et al. (2008)112 | Linac 6–18 MV | 3–10 coplanar or noncoplanar beams | NS | Abdominal compression | CT, MRI | Conformal planning | NS | Elekta ABC or abdominal compression | Orthogonal MV image guidance or kV cone beam CT imaging and kV orthogonal fluoroscopy
Aoki et al. (2007)4 | Linac EXL- 20TP Mitsubishi 10 MV | 4–6 fixed multiple noncoplanar conformal beams; 3 noncoplanar oblique anterior beams plus 2 coplanar oblique posterior beams plus 1 coplanar lateral beam | NS | Thermo-shell and custom made MoldCare head rest (Alcare) | CT | XiO version 4.1.1 CMS 3D radiotherapy treatment-planning machine/dose calculation with Clarkson method by 3D-RTP corrected for inhomogeneity | NS | NS | Electronic portal imaging device for tumor localization before each treatment
Brown et al. (2007)10 | CyberKnife 6MV | Noncoplanar beams | NS | NS | CT | Inverse planning module | Xsight Lung, fiducial markers | Breath hold, Synchrony | NS
Guckenberger et al. (2007)29 | NS | 5–7 coplanar and noncoplanar beams | NS | SBF (Elekta) | CT | NS | NS | Abdominal compression | CT simulation prior to treatment fractions
Hof et al. (2007)38 | Siemens linac 6MV | At least 6 different coplanar or noncoplanar isocentric beam directions | MLC leaf width at isocenter 1 cm | SBF with and vacuum pillow | CT | Voxelplan 3D treatment planning/pencil beam algorithm dose calculation | NS | Abdominal compression | NS
Hof et al. (2007)39 | Siemens Mevatron linac 6MV | 6–8 different coplanar or noncoplanar isocentric beam directions | MLC leaf width at isocenter 1 cm | SBF with vacuum pillow | CT | Voxelplan software DKFZ 3D treatment planning with/pencil beam algorithm dose calculation | Bony landmarks | Abdominal compression device | Orthogonal portal images compared to DRR
Hoopes et al. (2007)41 | NS | 7–10 noncoplanar compensated beams | NS | SBF (Elekta) | CT | 3D treatment planning | Prepatellar and sterna positioning marks permanently applied | Abdominal clamping pressure | NS
Koto et al. (2007)56 | Clinac 23Ex, Varian 6MV | Noncoplanar multi- dynamic arcs and/or multi-static beams | NS | Half body vacuum cast | CT | CadPlan and Eclipse 3D radiotherapy treatment-planning system/modified Batho power law tissue heterogeneity correction algorithm | Gold markers 3.0 × 0.8 mm | Respiratory gating and ABC | X-ray tubes mounted directly to gantry and 2 sets of amorphous silicon flat panel x-ray sensors
Muacevic et al. (2007)69 | CyberKnife 6MV | NS | NS | NS | NS | Inverse planning algorithm | Gold fiducials, Xsight | X-ray system | Orthogonally position x-ray cameras
Nuyttens et al. (2007)73 | CyberKnife 6MV | NS | NS | NS | NS | NS | NS | Synchrony | NS
Ponsky et al. (2007)81 | NS | NS | NS | Plastic mold | CT | Treatment-planning software | Gold fiducials, Xsight | NS | NS
Ricardi et al. (2007)82 | NS | 6–8 noncoplanar static multiple fields | NS | SBF | CT, PET | NS | NS | Diaphragm control device | NS
Scorsetti et al. (2007)90 | Linac | 4 or more dynamic arcs | 3D Line mMLC | Immobilization system with vacuum lock and/or thermoplastic mask | NS | 3D Line Medical Systems Ergo treatment-planning system | NS | NS | NS
Teh et al. (2007)107 | Novalis | NS | NS | Body cast | PET, CT, MRI | NS | Bony lesions or radio- opaque markers | Abdominal compression, gating, or ABC | Stereoscopic x-rays
Baumann et al. (2006)5 | Linac 6MV | 5–9 noncoplanar or coplanar beams | MLC | SBF(Elekta) | CT | 3D dose planning | NS | Diaphragm control device | CT scans for image guidance for verification
Dawson et al. (2006)20 | Elekta Synergy | 1–2 segments per beam when required to obtain optimal plans | NS | NS | 4D CT | Forward planning | NS | Breath hold using ABC | MV images and orthogonal kV fluoroscopic images
Ernst-Stecken et al. (2006)22 | Novalis | 1–6 either dynamic conformal arc or static conformal beams | NS | Self-constructed abdominal press | CT | Novalis BrainScan version 5.31 - Brain Lab/pencil beam algorithm dose calculation | NS | NS | ExacTrac
Hodge et al. (2006)37 | Tomotherapy Hi-Art | NS | NS | Custom made double vacuum | CT | Tomotherapy treatment-planning system | NS | Abdominal pressure pillow | MVCT scan and fused with planning CT
Hoyer et al. (2006)43 | Siemens Primus or Varian Clinac 2100/2300 6–8 MV | 5–8 static coplanar or noncoplanar beams | MLC leaf width 5–10 mm at isocenter | SBF (Elekta), vacuum pillow | CT | Helax-TMS or Varian CadPlan/Eclipse | Invasive skin marks | NS | Portal imaging
Joyner et al. (2006)47 | Linac | NS | NS | BodyFix (Medical Intelligence) | CT, PET | Nomos Corp Corvus treatment planning station 5.0/6.0 | NS | NS | CT imaging control
Le et al. (2006)59 | CyberKnife 6 MV | NS | NS | Vac Bag, MedTech | CT | NS | Fiducial markers on body immobilization or infrared markers on patients surface | Synchrony, Breath hold technique | Orthogonal x-ray image pairs
Madsen et al. (2006)63 | Linac | 6 stationary noncoplanar fields | Custom blocking | NS | CT, MRI | NS | 3 fiducial markers | NS | Isoloc Northwest Medical Physics Equipment for daily treatment position; orthogonal images
Nuyttens et al. (2006)72 | CyberKnife 6 MV | NS | NS | NR | CT | NS | Fiducial markers | Synchrony | 2 diagnostic x-ray sources with amorphous silicon detectors to acquire live digital radiographic images
Paludan et al. (2006)78 | Siemens Primus or Varian Clinac 2100/2300 | 5–8 static coplanar or noncoplanar beams | MLC | SBF (Elekta), vacuum pillow | CT | Helax TMS treatment-planning system/pencil beam algorithm tissue density inhomogeneity correction | Laser guided skin marks | NS | CT scan verification image
Romero et al. (2006)84 | Siemens Primus linac | 4–10 coplanar and noncoplanar beams | NS | SBF (Elekta) | CT | Varian CadPlan treatment planning system | Implanted gold fiducials | Abdominal compression | CT scan, electronic portal images
Sinha et al. (2006)95 | Linac 6 MV and 15 MV | 7–10 noncoplanar, nonopposing beams | NS | SBF (Elekta) | CT | 3D treatment planning | NS | Abdominal clamping pressure | NS
Svedman et al. (2006)103 | Linac 6MV | 5–8 coplanar or noncoplanar static beams | MLC | SBF (Elekta), vacuum pillow | CT | Helax TMS/pencil beam algorithm dose calculation | NS | NS | CT scan
Timmerman et al. (2006)108 | Linac | 10–12 noncoplanar, nonopposing beams | NS | SBF (Elekta), vacuum pillow | CT | Elekta Render 3D planning system | NS | Abdominal compression | NS
Wulf et al. (2006)119 | Elekta Synergy S 6–18 MV | Noncoplanar beams | NS | SBF (Elekta) | CT | Helax TMS version 4.01A, 4.01B, 5.1 and 6.1A Theranostic B.V 3D treatment planning system/pencil beam algorithm dose calculation | Fiducial markers in frame | NS | CT verification
Xia et al. (2006)120 | Body gammaknife 30 Co(60) | NS | 3, 12, 18 aperture diameter collimators | Vacuum bag | CT | NS | NS | NS | NS
Yoon et al. (2006)123 | NS | Coplanar and/or noncoplanar beams | NS | SBF (Elekta) | NS | Elekta 3D treatment- planning system Render plan | NS | ABC; diaphragm controller | NS
Zimmermann et al. (2006)124 | NS | Multiple static beams and/or dynamic arcs | MLC leaf width at isocenter 1 cm | Vacuum couch (Medical Intelligence) | CT | Siemens Helax TMS system/pencil beam algorithms | NS | NS | CT scans superimposed with ExacTrac
Hoyer et al. (2005)42 | Siemens Primus or Varian Clinac 2100/2300 | 5–8 static coplanar or noncoplanar beams | MLC leaf width 5–10 mm at isocenter | Vacuum pillow, SBF (Elekta) | CT | Helax-TMS or Varian CadPlan Plus/Eclipse | Skin marks | NS | Portal film or electronic portal imaging
Molla et al. (2005)365 | Novalis linac 6 MV | Dynamic arc treatments | mMLC | Customized vacuum body cast | CT | BrainLAB BrainScan TPS | NS | 5–7 infrared metallic markers asymmetrically fixed to skin of abdomen before treatment planning | ExacTrac, Infrared cameras mounted to the ceiling
Shioyama et al. (2005)94 | Clinac 12 Ex Varian 6 or 10MV | 5–8 noncoplanar static ports | MLC | Thermoplastic body cast with vacuum pillow and arm & leg holding devices (Ximatron Varian) | CT | Varian Eclipse version 6.5 3D RT treatment planning machine | X-ray simulator for tumor | Respiratory gating | CT verification
Song et al. (2005)97 | NS | 4–8 coplanar beams or single plane dynamic arcs | NS | Custom fitted immobilization | CT | BrainLAB version 5.2/tissue maximum ratio calculation algorithm; Philips Pinnacle3 monitor units confirmed/inhomogeneity corrections | 6–7 infrared reflective skin markers and lateral isocenter tattoos | NS | Infrared marker system, orthogonal films, CT verification
Beitler et al. (2004)7 | NS | Coplanar and noncoplanar arrangements | NS | SBF | CT | NS | Fiducial markers on the box | NS | NS
Ishimori et al. (2004)44 | Clinac 2300 6MV Varian | 6–10 field noncoplanar | NS | SBF (Elekta) | NS | Varian 3D treatment- planning system CadPlan R.6.0.8 | NS | NS | NS
Onishi et al. (2004)77 | EXL-15DP Mitsubishi | 10 different noncoplanar dynamic arcs | NS | NS | CT | CMS 3D treatment- planning computer FOCUS version 3.2.1 | Skin marker | Self breath hold | Electronic portal imaging
Gerszten et al. (2003)26 | CyberKnife 6MV | NS | NS | NS | CT | Inverse treatment plan | Fiducial placement | NS | Two diagnostic x-ray cameras orthogonal to acquire real time images
Gunven et al. (2003)32 | Linac 6MV | NS | NS | Stereotactic frame | CT | NS | NS | External abdominal pressure | NS
Lee, et al. (2003)60 | NS | 4–8 field coplanar and/or noncoplanar beams | MLC with 1 cm thick leaves | SBF with vacuum pillow | CT | Elekta 3D planning system Render Plan | NS | Diaphragm controller | CT scan and verification films before each treatment
Whyte et al. (2003)117 | CyberKnife 6MV | NS | NS | Alpha cradle (Smithers Medical) | CT | CyberKnife inverse planning system and nonisocentric radiation delivery | Implanted metal fiducial markers | Breath hold technique or tracking LEDs placed on the patient’s skin | Real-time image processing
Harada et al. (2002)35 | Linac | NS | NS | NS | NS | 3D radiotherapy planning system | Gold marker | NS | X-ray system in floor and on ceiling
Uematsu (2001)113 | Fusion of CT and linac (FOCAL) | NS | NS | NR | NS | NS | NS | Abdominal pressure belt and/or shallow respirations with oxygen mask | NS
Wulf et al. (2001)118 | Linac 5–18 MV | Symmetric 5 beam arrangement individualized by addition of rotational beams or opposing beams | NS | SBF, vacuum pillow | CT | Helax TMS version 4.01A and 4.01B MDS Nordion 3D treatment planning system | NS | Diaphragm control device | CT verification
Nakagawa et al. (2000)70 | NS | NS | Dynamic MLC | NS | CT | NS | NS | NS | MV CT-assisted verification

2D: Two-dimensional

3D: Three-dimensional

4D: Four-dimensional

ABC: Active breathing control

CT: Computed tomography

DRR: Digitally reconstructed radiographs

IMRT: Intensity modulated radiation therapy

kV: Kilovolt

LED: Light emitting diode

MEV: Million electron volt

mm: Millimeter

MRI: Magnetic resonance imaging

MV: Megavolt

mMLC: micro-Multileaf collimator

MLC: Multileaf collimator

NS: Not specified

PET: Positron emission tomography

SBF: Stereotactic body frame