# Results for Guiding Question 3

Prospective Single Group Studies

Study | Country | Cancer Type | Instrumentation/Algorithms | Study Size | Prior or Concurrent Treatment | Length of Followup (Months) | Outcomes Measured | Adverse Events
Freeman et al. (2011)23 | USA | Low-risk prostate cancer | Cyberknife/NR | n = 41 | None | Median: 60 (Range: 50.4– 74.4) | PSA levels; toxicity; QoL | Acute: dysuria, urinary urgency, frequency, nocturia, tenesmus Late: grade 1N3 urinary, grade 1N2 rectal
Aluwini et al. (2010)3 | The Netherlands | Low to intermediate risk prostate cancer | Cyberknife/NR | n = 10 | NR | Median: 5.1 (Range: 2–13) | Early and intermediatiat toxicity scores; early PSA response | Acute grade 1N2: rectal bleeding; urinary toxicity
Bolzicco et al. (2010)8 | Italy | Prostate cancer | Cyberknife/NR | n = 22 low risk n = 23 intermediate risk | Prior: hormone therapy; transurethral resection n = 17 concurrent androgen deprivation | Median: 20 (Range: 6–42) | Toxicity; PSA response | Grade 1–3: urgency, urinary frequency, rectal urgency or stool frequency Late: occasional rectal bleeding
Bradley et al. (2010)9 | Italy | Stage I NSCLC | NR/NR | n = 91 | None | Median: 18 (Range: 6–42) | Local control; nodal failures; distant failures | Skin reaction; grade 2 radiation pneumonitis; painful subcutaneous inflammatory reaction adjacent to treated chest wall; rib fracture; chest wall pain at site of treatment; brachial plexopathy
Cardenes et al. (2010)11 | USA | Primary HCC | Linac/NR | n = 17 with 25 lesions | None | Median: 24 (Range: 10–42) n = 10 patients alive without progression | Toxicity; tumor response; maximum tolerated dose; survival | Grade 3 and higher: elevation of bilirubin, hypokalaemia, hyperbilirubinaemia, radiation induced liver disease
Goodman et al. (2010)27 | USA | Primary and metastatic liver tumors | Cyberknife/NR | n = 19 hepatic mets n = 5 IHCC n = 2 recurrent HCC | None | Median: 17.3 (Range: 2–55) | Local control; survival; overall survival, | Grade 1: nausea, abdominal pain, fever, fatigue Grade 2: duodenal ulcer, gastrointestinal bleeding, musculoskeletal toxicity
Kopek et al. (2010)55 | Denmark | Cholangiocarcinoma | Siemens Primus/NR | n = 27 | None | Median: 64.8 (Range: 27.6–103.2 entire cohort) | Local control; progression- free survival; overall survival; acute and late radiation induced toxicities | Grade ≥3 nausea, vomiting, pain, analgesia, ulceration, duodenal stenosis, hepatic failure
Oermann et al. (2010)74 | USA | Prostate cancer | Cyberknife/Inverse treatment plan | N = 13 intermediate risk N = 11 high risk | Concurrent: IMRT given immediately after SBRT | Median: 9.3 (Range: 6.6– 16.9) | Toxicity; QoL; PSA response | Grade 2: urinary symptoms requiring alpha blockers; bowel frequency/spasms requiring antidiarrheals
Polistina et al. (2010)80 | Italy | Locally advanced pancreatic adenocarcinoma | CyberKnife/NR | n = 23 | None | Mean: 11 +3.95 Median: 9 | Gastrointestinal toxicity; tumor response; local control; pain; QoL; overall survival time | n = 5 grade 1 vomiting/nausea; n = 3 enteric bleedings diagnosed endoscopically as bleeding from duodenal wall cancer invasion
Shin et al. (2010)93 | Korea | HCC | Cyberknife/Pencil beam | n = 6 | n = 6 prior TACE | Three alive patients: Median: 25.9 (Range: 8.1–56) | Tumor response; local failure; acute and late toxicities; radiation induced liver disease; dose limiting toxicity; survival | Alkaline phosphatase and liver enzymes increased due to disease progression During treatment: mild nausea, transient asymptomatic, right-sided pleural effusion
Stintzing et al. (2010)101 | Germany | Metastatic liver tumors of colorectal cancer | Cyberknife/NR | n = 14 | n = 6 prior chemo; n = 9 prior surgery; n = 1 prior chemo- embolization | Median: 16.8 | Local control; toxicity; progressional- free survival; overall survival | No patients reported side- effects of RT; bleeding, ulcers, or strictures have not been detected
Stintzing et al. (2010)102 | Germany | Liver tumors | Cyberknife/NR | n = 36 with 54 mets | Prior: chemo; surgery; RFA; chemoembolization; selective internal radiotherapy; laser- induced thermal therapy | Median: 21.3 (Range: 2.8–44) | Local tumor control; survival; toxicity | Grade 1 fatigue and nausea
Timmerman et al. (2010)109 | USA | Early stage inoperable NSCLC | Linac/NR | n = 55 | None | Median: 34.4 (Range: 4.8–49.9 all evaluable) Median: 38.7 (Range: 30.2–49.9 still living) | Tumor response; 3 year primary tumor control rate; local and regional failures; 3 year rates disseminated recurrence; disease-free survival; overall survival | Grade 1–5 toxicities; n = 6 events related to SBRT (n = 3 complications of skin or ribs)
Vahdat et al. (2010)115 | USA | Inoperable stage IA NSCLC | CyberKnife/NR | n = 20 | None | Median: 43 | Disease spread; survival; serial change in maximum standardized uptake value (SUV[max]); local control | Radiation induced pneumonitis and infiltrating lung fibrosis
Collins et al. (2009)17 | USA | Stage 1 NSCLC | CyberKnife/Inverse-planning algorithm | n = 20 | n = 1 concurrent gefitinib treatment | Median: 25 (Range: 6–36 for survivors) | Pulmonary status; tumor response; disease progression; survival | Pneumothorax requiring tube thoracotomy (after fiducial placement); mild transient fatigue; chest wall discomfort; acute grade III radiation pneumonitis and infiltrate; hypoxia
Haasbeek et al. (2009)33 | The Netherlands | Second lung tumor in the contralateral lung | Linac/NR | n = 15 | Prior pneumonectomy for an earlier lung tumor; radiation therapy | Median: 16.5 (Range: 4–55) | Overall survival; distant metastasis free survival; local control; regional failure free survival; disease-free survival; toxicity | Mild fatigue, grade 3 late toxicity; grade 3 radiation pneumonitis; grade 3 complication
Kim et al. (2009)52 | Korea | Pulmonary metastatic colorectal cancer | CyberKnife/NR | n = 13 | Prior chemo; surgery | Median: 28 (Range: 15–57) | Overall survival; local control; progression- free survival | Grade 1–2 toxicities: musculoskeletal discomfort and asymptomatic radiation pneumonitis
Kopek et al. (2009)54 | Denmark | Early stage NSCLC | Linac/NR | n = 88 | None | Median: 44 (Range: 1.6– 96.5) | Tumor response; actuarial local control; freedom from failure; median cancer-specific survival; overall survival | Deterioration in performance status by >3 grade points, >3 grade point worsening in analgesia use, 3 grade point deterioration in dyspnea; rib facture
Lee et al. (2009)61 | Canada | Liver metastases | Linac/NR | n = 68 | n = 7 prior surgery; n = 8 prior RFA; prior lines of chemo: n = 9 (0), n = 15 (1), n = 29 (2), n = 15 (>3); n = 1 prior Whipple operation and prior radiotherapy to celiac axis lymph nodes | Median: 10.8 | Maximum tolerated study dose (MSD); tumor response; local control; progression- free survival; overall survival | Grade 3 or higher acute toxicity; thrombocytopenia; grade 3 liver enzymes; subacute liver pain; transient gastritis/esophagitis; grade 2 colitis Late: grade 4 duodenal bleed; grade 5 malignant small bowel obstruction; grade 4 small bowel obstruction through an abdominal hernia; grade 2 nontraumatic rib fractures; transient grade 2 chest wall pain; grade 2 dyspepsia
Milano et al. (2009)67 | USA | Oligometastases | Novalis linac/NR | n = 32 | n = 10 prior curative intent local therapy; n = 9 prior resection; n = 1 prior radio- frequency ablation (RFA); n = 1 prior radiation therapy (RT) | Median (deceased): 8 (Range: 3–20); Median (survivors): 7 (Range: 2–32) | Overall survival; progression- free survival; local failure | NR
Olsen et al. (2009)75 | USA | Liver metastases | Linac/NR | n = 15 | None | NR | Change in normal liver volume | NR
Rusthoven et al. (2009)86 | USA | Liver metastases | Linac/NR | n = 47 | Mean 1.7 (Range: 0–7) prior systemic treatment regimens; n = 7 prior local therapy for liver metastases | Median: 16 (Range: 6–54) | Local control, toxicity; progression- free survival; distant progression- free survival; overall survival | Grade 3 soft tissue toxicity: skin erythema, pain
Rusthoven et al. (2009)87 | USA | Lung metastases | Linac/NR | n = 38 | Mean 1.2 (Range: 0–5) prior systemic therapy regimens for metastatic disease | Median: 15.4 (Range: 6–48) | In-field local control; overall survival; toxicity; distant progression; local progression; distant progression-free survival | Grade 3 toxicity rib fracture; grade 2 radiation dermatitis; grade 1 pneumonitis; symptomatic radiation pneumonitis
van der Voort van Zyp et al. (2009)116 | The Netherlands | NSCLC | CyberKnife/NR | n = 70 | None | Median: 15 | Local control; overall survival; cause-specific survival | Fiducial placement: grade 3 toxicity (pneumothorax requiring a chest drain and cardiac arrhythmia required a pacemaker); grade 2 toxicity pneumothorax but required no chest drain; grade 1 toxicity: minor dyspnea, pneumothorax without clinical symptoms, and self-limiting pulmonary hemorrhage After treatment: acute grades 1–2 toxicity (fatigue, dyspnea, cough); acute grade 3 toxicity requiring morphine, late grade 3 toxicity, radiation pneumonitis, thoracic pain, rib fracture
Chang et al. (2008)13 | USA | Centrally and superiorly located stage 1 NSCLC or isolated lung parenchymal recurrent NSCLC | Linac/NR | n = 27 | None | Median: 17 (Range: 6–40) | Local control; tumor response | Grade 2 pneumonitis; grade 2–3 dermatitis and chest wall pain; brachial plexus neuropathy; partial arm paralysis
Fuller et al. (2008)25 | USA | Prostate cancer | CyberKnife/NR | n = 10 | Concurrent distribution of high dose rate brachytherapy | 2 week, 4 week, 8 week, and 4 month follow-up done | Early PSA response | No urinary obstruction observed to date, mild and transient rectal toxicity; no acute rectal bleeding observed
Henderson et al. (2008)36 | USA | Inoperable stage 1 NSCLC | Linac/NR | n = 70 | None | Median: 2.17 years (Range: 0.12– 3.62 years) | Survival; pulmonary function | Grade 2 or higher pulmonary toxicity: pneumonitis, pneumonia, and other pulmonary toxicity
Katoh et al. (2008)49 | USA | Adrenal tumors | Linac/NR | n = 9 | None | Median: 16 (Range: 5–21) | Disease progression; local failure | No decline in hormone level, tumor-related flank pain
Salazar et al. (2008)88 | USA | Primary and metastatic lung cancer | Linac/NR | n = 104 | n = 29 concurrent external beam radiation therapy (EBRT) | Median: 38 (Range: 2–84) | Local tumor response; local tumor control; failure analysis | [underlined: Grade 1 and 2 acute toxicity]: shortness of breath, fatigue, cough, esophagitis, nausea and vomiting, nonmalignant symptomatic pleural effusion, skin reaction; [underlined: Grade 2 symptomatic subacute or chronic toxicities]: symptomatic RT-induced pneumonitis, severe symptomatic fibrosis with sustained shortness of breath; asymptomatic fibrosis of varying degrees
Schellenberg et al. (2008)89 | USA | Adenocarcinoma of the pancreas | CyberKnife/NR | n = 16 | Gemcitabine infusion chemo dose of 1,000 mg/m^2^ weekly | Median: 9.1 for all patients; Median: 22.3 for living patients | Local control, toxicities, time to progression, overall survival, carbohydrate antigen (CA 19–9) levels | Pain and gastritis (n = 3); 1 patient required J-tube placement 6 weeks after treatment which was attributed to the SBRT [underlined: Late toxicities]: n = 5 treated medically for ulcer formation (grade 2), 1 required duodenal stent for a non-neoplastic stricture (grade 3), and 1 required surgery after duodenal perforation (grade 4)
Tse et al. (2008)112 | Canada | Unresectable hepatocellular carcinoma (HCC) and intrahepatic cholangio- carcinoma (IHC) | NR/NR | n = 41 | NR | Median: 17.6 (Range: 10.8– 39.2) | Survival; local control rate; overall RECIST response rate (complete response, partial response, stable disease) | Transient biliary obstruction; death result of a pulmonary embolus; grade 3 liver enzymes; grade 3 thrombocytopenia; transient asymptomatic right- sided pleural effusion; progression from Child-Pugh A classification to B; late toxicity
Aoki et al. (2007)4 | Japan | Primary lung or metastases | Mitsubishi EXL-20TP 10-MV standard linac/NR | n = 19 | n = 10 repeat SRT; n = 1 prior RT | Median: 17.7 (Range: 9.4– 39.5) | Tumor response; crude local tumor control rate; overall survival rate (Kaplan-Meier) | Grade 1 radiation pneumonia; grade 1 radiation fibrosis
Hof et al. (2007)38 | Germany | Pulmonary metastases | NR/Pencil beam algorithm for dose calculation | n = 61 | None | Median: 14 (Range: 1.5–82) | Local control | Grade 1, 2, 3 toxicities
Hof et al. (2007)39 | Germany | Early stage lung cancer | Siemens Mevatron Linac/Pencil beam algorithm for dose calculation | n = 42 | None | Median: 15 (Range: 1.5–72) | Actuarial overall survival rates & local tumor control rates (Kaplan-Meier) | Minor cough; slightly increased dyspnea
Hoopes et al. (2007)41 | USA | NSCLC | NR/NR | n = 58 | None | Median: 42.5 (Range: 27–61) | Local failure; regional progression; metastatic dissemination | NR
Koto et al. (2007)56 | Japan | Stage 1 NSCLC | Varian Clinac 23EX/NR | n = 31 | None | Median: 32 (Range: 4–87) | 3-year overall survival rate; cause specific survival after 3 years | Grade 1 acute pneumonitis; grade 2 acute pneumonitis; grade 3 acute pneumonitis
Madsen et al. (2007)63 | USA | Localized prostate cancer | NR/NR | n = 40 | None | Median: 41 (Range: 12–60) | PSA levels | [underlined: Acute:] rectal discomfort, constipation, diarrhea, tenesmus [underlined: Late:] proctitis, occasional blood, rectal discomfort, frequent stools, constipation, diarrhea
Muacevic et al. (2007)69 | Germany | Lung tumors | CyberKnife/Nonisocentric inverse planning algorithm | n = 15 | None | 2 month intervals | NR | Pneumothorax; nausea; pneumonitis
Nuyttens et al. (2007)73 | The Netherlands | Metastases (para- aortic or pelvic lymph nodes, abdominal wall, muscle tissue, rib, retroperitoneal fat, local recurrences in pelvis, neck) | CyberKnife/NR | n = 14 | n = 3 prior chemo; n = 3 prior surgery; n = 4 prior irradiation | Median: 18 (Range: 6–26) | Local failure; local regional progression; tumor progression at a distance or new metastasis; local control and disease- free survival calculated Kaplan-Meier method; toxicity | [underlined: Acute:] transient grade 1 lymphedema in leg, grade 1 abdominal pain, nausea, and diarrhea; grade 1 dermatitis; [underlined: Late:] grade 1 rectal bleeding, chronically painful grade 2 subcutaneous fibrosis, grade 1 diarrhea, grade 2 pain in surgical scar on belly
Ponsky et al. (2007)81 | USA | Renal | NR/NR | n = 3 | Partial or radical nephrectomy 8 weeks after RS | Mean: 12.8 (Range: 12–14) | Tumor response | None reported
Ricardi et al. (2007)82 | Italy | NSCLC | NR/NR | n = 43 | None | Median: 14.7 (Range: 3–44) | Tumor control, complications | Temporary erythema; radiation pneumonitis (grade 1); acute pneumonitis; rib fracture; thoracic pain
Scorsetti et al. (2007)90 | Italy | NSCLC | Linac/NR | n = 43 | NR | Median: 14 (Range: 6–36) | Actuarial survival; morbidity | Acute and late grade I or grade II
Dawson et al. (2006)20 | Canada | Hepatocellular carcinoma, intrahepatic cholangio- carcinoma, liver metastases | Elekta Synergy/NR | n = 79 | NR | Maximum: 34 | Primary end point: rate of radiation- induced liver toxicity or severe toxicity occurring within three months of treatment | None observed
Ernst-Stecken et al. (2006)22 | Germany | Lung cancer, thyroid cancer | Novalis/Dose calculation done by pencil beam algorithm | n = 21 | None | Median: 6.3 (Range: 1–21) | Quality of hFSRT; local tumor control; survival | Grade 1 and 3 toxicity
Hodge et al. (2006)37 | USA | NSCLC | Tomotherapy Hi-Art/NR | n = 9 | n = 2 single IMRT | Median: 2.1 (Range: 1.8– 13.3) | Tumor response | No reports of grade 2 or higher acute toxicity
Hoyer et al. (2006)43 | Denmark | Colorectal metastases | Siemens Primus or Varian Clinac 2100/2300/NR | n = 65 | n = 16 surgery; n = 4 RFA or other treatment; n = 33 neoadjuvant chemo | Median: 51.6 (Range: 2.4– 75.6) | Survival (Kaplan-Meier); tumor response (local control, local or distant progression); survival; toxicity | Death related to hepatic failure; perforation of colonic ulceration; duodenal ulceration; abdominal pain, increased consumption of analgesics; grade 2 or higher pain score; WHO performance status deterioration; moderate nausea; moderate diarrhea; skin toxicity
Le et al. (2006)59 | USA | NSCLC or metastases | CyberKnife/NR | n = 32 | n = 10 prior lung resection; n = 6 prior thoracic RT; n = 10 prior systemic therapy | Median: 18 (Range: 9–32) | Treatment response - partial response; minor response; stable disease | Pneumothorax; mild COPD; grade 2 to 3 pneumonitis
Nuyttens et al. (2006)72 | The Netherlands | Early stage lung cancer | CyberKnife/NR | n = 20 | None | Median: 4 (Range: 2–11) | Tumor response | Intrathoracic pain
Romero et al. (2006)84 | The Netherlands | Primary liver tumors and metastases | Siemens Primus linac/NR | n = 25 | None | Median: 12.9 (Range: 0.5–31) | Local control and survival (Kaplan-Meier) | Decompensated portal hypertension; bleeding from esophageal varices; ascites grade 2; elevation of gamma glutamyl transferase (GGT) grade 3; asthenia grade 3
Svedman et al. (2006)103 | Sweden | Primary and metastatic renal cell carcinoma | Linac 6MV/NR | n = 30 | n = 26 nephrectomy; n = 2 interferon alpha; n = 2 tamoxifen | Median: 52 (Range: 11–66) | Local tumor response (primary); toxicity, pain, and survival (secondary endpoint) | Cough, fatigue, skin rash, focal pain, one patient died— cannot be ruled out may have been treatment-related
Timmerman et al. (2006)108 | USA | Early stage NSCLC | Linac/NR | n = 70 | None | Median: 17.5 (Range: 0.6– 44.2) | Tumor response, disease control, survival | Grade 5 toxicities resulting in 6 deaths due to lung cancer treatment: 4 associated with bacterial pneumonia, 1 as a result of complications from pericardial effusion, 1 associated with massive hemoptysis; grade 3–4: decline in pulmonary function tests, pneumonitis, pleural effusions, apnea, skin reaction; grade 1–2: fatigue, musculoskeletal discomfort, radiation pneumonitis
Wulf et al. (2006)119 | Germany | Primary liver cancer and hepatic metastases | NR/Dose distribution calculated based on a pencil beam algorithm | n = 56 | None | Median: 15 (Range: 2–48) | Local tumor control; local failure; Secondary: treatment- related acute and late toxicity; freedom from systemic progression; overall survival | Pain; fever; chills; liver fibrosis; portal hypertension; ascites; bleeding from esophageal varices
Yoon et al. (2006)123 | South Korea | Thoracic (38 primary or 53 metastatic) | NR/NR | n = 91 | NR | Median: 14 (Range: 4–56) | Overall response | None greater than RTOG toxicity criteria grade 2 were observed
Xia et al. (2006)120 | USA & China | Stage 1 or Stage 2 NSCLC | Gamma-knife (30 rotary conical surface Cobalt 60); NR | n = 43 | None | Median: 27 (Range: 24–54) | Local tumor control – complete response; partial response; progressive disease | Acute radiation induced esophagitis; acute radiation induced pneumonitis; mild radiation induced acute whole body reactions (anorexia, nausea, and vomiting); grade 1 neutropenia; late radiation induced local fibrosis
Zimmermann et al. (2006)124 | Germany | Stage 1 NSCLC | NR/NR | n = 68 | None | Median and Mean: 17 (Range: 3–44) | Tumor response— complete remission; partial remission; local progression; distant progression; overall and cancer-specific survival; acute and late toxicity | Pneumonitis; late lung fibrosis; fatigue; shivering; nausea; dermatitis; benign pleural effusion; rib fracture; fibrosis of soft tissue
Hoyer et al. (2005)42 | Denmark | Pancreatic cancer | Siemens Primus or Varian Clinac/NR | n = 22 | None | 2–34 | Toxicity; tumor response; overall survival; progression- free survival | Severe mucositis or ulceration of stomach or duodenum; perforation of stomach due to ulcer
Shioyama et al. (2005)94 | Japan | Lung and liver tumors | Varian Clinac 21 Ex/NR | n = 20 | None | 1–15 | Accuracy of fixation; local tumor response; survival and local rates calculated by Kaplan-Meier method; toxicities | NCI-CTC grade 2 complications
Song et al. (2005)97 | USA | Lung tumors | NR/Tissue maximum ratio calculation algorithm | n = 17 | None | Median: 14 | Tumor response; toxicity | Fatigue; mild rib pain & tenderness; rib fracture; nonproductive cough; dyspnea; bronchial stenosis; collapse
Ishimori et al. (2004)44 | Japan | Solitary lung cancer | Varian Clinac 2300 C/D/NR | n = 9 | None | Range: 2–17 | Local response – complete response; partial response; no change; progressive disease | Radiation induced pneumonitis
Onishi et al. (2004)77 | Japan | Stage 1 NSCLC | Linac/NR | n = 35 | None | Range: 6–27 | Locally progression; tumor response | Acute interstitial pneumonitis
Gerszten et al. (2003)26 | USA | Sacrum | CyberKnife/NR | n = 18 | n = 15 prior EBRT | NR | Pain improvement | No acute radiation toxicity or new neurological deficits occurred
Lee et al. (2003)60 | South Korea | Primary and metastatic lung tumors | NR/NR | n = 28 | NR | Median: 18 (Range: 7–35) | Survival time (Kaplan-Meier method); acute toxicity; late complications; response to radiation; patterns of treatment failure | All patients developed grade 1 radiation pneumonitis within 3 months; none had symptomatic complications after SRS treatment.
Whyte et al. (2003)117 | USA | Primary lung cancer and metastases | CyberKnife/Nonisocentric inverse-planning algorithm | n = 23 | n = 1 right lower lobectomy | Mean: 7 (Range: 1–26) | Complete tumor response; Partial tumor response; Stable; Progressive; Death of nontreatment related causes | Pneumothoraces; exacerbation of underlying chronic obstructive pulmonary disease
Harada et al. (2002)35 | Japan | Lung tumors | NR/NR | n = 18 | n = 1 prior RT | Median: 9 (Range: 5–15) | Overall response rate | Pneumonitis
Uematsu et al. (2001)113 | Japan | Stage 1 NSCLC | FOCAL unit (combination of linac, CT scanner, X-ray simulator, carbon table)/NR | n = 50 | n = 18 prior conventional treatment (40–60 Gy in 20–33 fractions, 4–6 weeks) | Median: 36 (Range: 22–66) | Overall cause specific survival rates (Kaplan-Meier Method); local control | Rib fracture; vertebral compression fracture; mild and temporary pleural pain; lung fibroses and/or atelectasis
Wulf et al. (2001)118 | Germany | Lung and liver | NR/NR | n = 51 | n = 18 chemo | Median lung: 8 (Range: 2–33); Median liver: 9 (Range: 2–28) | Crude local control; actuarial local control; actuarial overall patient survival | Grade 1/2; grade 3; grade 4; grade 5
Nakagawa et al. (2000)70 | Japan | Thoracic neoplasms | Megavoltage computed tomography assisted SRS/NR | n = 15 | n = 1 prior Gamma Knife SRS to a solitary brain metastasis; n = 8 conventional fractionated RT following SRS | Median: 10 (Range: 2–82) | Tumor response; survival | No patient reported adverse acute symptoms; all patients who survived for over 3 months showed some interstitial change in the local lung tissue.

COPD: Chronic obstructive pulmonary disease

CT: Computed tomography

EBRT: External beam radiation therapy

HCC: Hepatocellular carcinoma

hFSRT: Hypofractionated stereotactic radiotherapy

IHCC: Intrahepatic cholangiocarcinoma

IMRT: Intensity modulated radiation therapy

NCI-CTC: National Cancer Institute-Common Toxicity Criteria

NSCLC: Non-small cell lung cancer

NR: Not reported

PSA: Prostate specific antigen

QoL: Quality of life

RECIST: Response evaluation criteria in solid tumors

RFA: Radiofrequency ablation

RS: Radiosurgery

RT: Radiation therapy

RTOG: Radiation Therapy Oncology Group

SBRT: Stereotactic body radiation therapy

SRS: Stereotactic radiosurgery

TACE: Transcatheter arterial embolization

WHO: World Health Organization

Retrospective Studies

Study | Country | Cancer Type | Instrumentation/Algorithms | Study Size | Prior or Concurrent Treatment | Length of Followup (Months) | Outcomes Measured | Adverse Events
Crabtree et al. (2010)19,* | USA | Stage I NSCLC | Trilogy/NR | n = 76 treated with SBRT n = 462 treated with surgical resection | None | SBRT Median: 19 Surgical Median: 31 | Local recurrence; disease- specific survival; overall survival | SBRT: grade 1–2 pneumonitis; grade 3 pnuemonitis; rib fractures; pleural effusions; lung collapse; hemoptysis; bacterial pneumonia Surgery: arrhythmias; pneumonia/respiratory
Dunlap et al. (2010)21 | USA | Primary NSCLC | Hi-Art Helical TomoTherapy/Inverse planning software | n = 60 | None | Median: 12.5 (Range: 2–35) Median: 11.1 (Range: 3–35) | Tumor response; local recurrence; regional nodal recurrence, distant systemic metastases; survival; local control | Chest wall pain; rib fracture; symptomatic pulmonary complications (>grade 1); grade 3–4 pneumonitis
Grills et al. (2010)28,† | USA | Stage I NSCLC | NR/NR | n = 55 treated with SBRT n = 69 treated with wedge resection | None | Median: 30 | Regional recurrence; locoregional recurrence; distant metastasis; freedom from any failure; overall survival; cause-specific survival | Grade 2–3 radiation pneumonitis; rib fractures; grade 1 skin toxicities; acute or chronic myositis
Guckenberger et al. (2010)31 | Germany | Locally recurrent gynecological cancer | Linac/NR | n = 12 cervical cancer n = 7 endometrial cancer | n = 12 prior surgery n = 6 prior surgery and adjuvant RT n = 1 prior RT n = 6 concurrent EBRT followed by SBRT boost | Median: 22 | Survival; systemic control; local control | Acute: grade 2 diarrhea, nausea, proctitis, dysuria, dermatitis; grade 3 pollakisuria Late: grade 2 proctitis, nausea, stenosis of yereter, neuralgic pain; grade 4 small bowel ileus, intestine vaginal fistula
Hamamoto et al. (2009)34 | Japan | Primary lung cancer and metastatic lung tumors | Linac/Pencil beam | n = 52 primary lung cancer n = 10 metastatic lung tumors | n = 2 prior intravenous systemic chemo | All tumors Median: 14 (Range: 3–34) Primary Median: 14 (Range: 3–34) Metatastic Median: 19 (Range: 9–31) | Overall survival; local control | None reported
Jorcano et al. (2010)46 | Switzerland | Gynecologic tumors | Novalis/NR | n = 9 cervical cancer n = 17 endometrial cancer | Prior: hysterectomy, pelvic lymphadenectomy, chemo, para-aortic irradiation, WPRT Concurrent: traditional RT followed by SBRT boost | Median: 47 (Range: 4–77) | Toxicity; local disease control; distant failures; overall survival; failure-free survival rate | Acute: grade 0–2 sexual, grade 0–3 urinary, grade 0–3 rectal Late: grade 0–3 sexual, grade 0–2 urinary, grade 0–3 rectum
Kang et al. (2010)48 | Korea | Oligometastases confined to one organ from colorectal cancer | Cyberknife/NR | n = 55 with 78 lesions (lung, liver, pelvic aortic lymph nodes, mediastinal lymph nodes, bone) | n = 21 prior curative intent local therapy (resection, RFA) n = 49 prior chemo | Median: 32 (Range: 9–80) | Tumor response; toxicity; local control; overall survival | Acute: grade 1–2 - nausea, vomiting, musculoskeletal discomfort; grade 4 intestinal perforation, obstruction
Kim et al. (2010)53 | Korea | Nonanaplastic thyroid cancer | Cyberknife/NR | n = 9 | n = 3 prior neck RT, neck surgery, radioisotope | Median: 23 (Range: 4–63) | Tumor response; regional failure | No grade 3 or higher Adverse events
Louis et al. (2010)62 | Belgium | HCC | Cyberknife/NR | n = 25 | n = 3 prior chemoembolization n = 1 prior sorafenib n=3 prior surgery n = 2 prior radiofrequency ablation | Median: 12.7 (Range: 1–24) | Local control; tumor response; toxicity; survival; overall survival; disease free survival | Acute: grade 3 liver pain; grade 3 hepatic toxicity; grade 2 digestive in nature Late: grade 2–3 duodenal ulcers
Mahadevan et al. (2010)64 | USA | Nonmetastatic locally advanced unresectable pancreatic cancer | CyberKnife/NR | n = 36 | None | Median: 24 (Range: 12–33) | Local control; acute toxicity; local and distant progression; overall survival | Fatigue; nausea; persistent nausea; cramping, vomiting, dehydration; worsening inferior vena cava thrombosis that developed at exploratory laparotomy; gastrointestinal bleeding requiring transfusion (late toxicity)
Seok Seo et al. (2010)91 | Korea | Inoperable HCC | Cyberknife/NR | n = 38 | n = 38 prior TACE | Median: 15 (Range: 3–47) at this time 17 patients had died | Local progression- free survival; disease progression- free survival; overall survival | Grade 1–2: decline in liver function; acute radiation dermatitis with wet desquamation Grade 3: soft tissue toxicity
Son et al. (2010)96 | South Korea | Small unresectable primary hepatocellular carcinoma | CyberKnife | n = 36 | None | NS | Radiation induced hepatic toxicity; deterioration of hepatic function | Grade 2–4 toxicities
Takeda et al. (2010)106 | Japan | Primary lung cancer and metastatic lung tumors | NR/superposition algorithm | n = 111 primary lung cancer n = 22 lung metastasis | None | Median: 12 (Range: 5–45) | Toxicity | Grade 0–3 radiation pneumonitis
Townsend et al. (2010)110 | USA | Prostate cancer | CyberKnife/NR | n = 48 | n = 11 IMRT, Tomotherapy followed by SBRT boost | Mean: 2.76 Median: 2.64 | Acute gastro- intestinal and genitourinary toxicities | Mild increase in frequency/nocturia; acute grade 1–3 gastrointestinal and genitourinary
Trovo et al. (2010)111 | USA | Lung cancer | Trilogy/superpositi on convolution algorithm | n = 68 with 70 tumors | None | Four follow-up periods: 6 weeks; 2–6 months; 7–12 months; 13–18 months after SBRT | Radiographical changes; toxicity; local control | Pleural thickening; pleural effusion; bronchiectasis; radiation fibrosis Late radiographical injuries; grade 2 lung toxicity; grade 2 pulmonary toxicity; grade 2–4 emphysema
Unger et al. (2010)114 | USA | Primary hilar lung cancer or hilar lung metastases | Cyberknife/Non- isocentric, inverse-planning algorithm | n = 20 | None | Median: 10 | Local tumor recurrence; toxicity; overall survival | Acute grade 2 esophagitis; dyspnea and infiltrate; mainstem bronchus fistula; mild fatigue
Yamashita et al. (2010)121 | Japan | Primary lung cancer and metastatic or recurrent lung cancer | Synergy/Collapsed cone convolution | n = 74 primary lung cancer n = 43 metastatic or recurrent lung tumors | None | Median: 14.7 (Range: 0.3– 76.2) | Toxicity | Grade 0–5 radiation pneumonitis
Yang et al. (2010)122 | China | HCC | Body Gamma Knife treatment system/NR | n = 40 | Prior and Concurrent: n = 17 prior and concurrent rAd-p53 (recombinant adenovirus-mediated wild-type p53 gene – rAd-p53) | Median: 35 (Range: 11–44) | Response; toxicity; survival | Grade 1–2: Fever; gastrointestinal toxicity; abnormal liver function; thrombocytopenia; leukopenia
Hof et al. (2009)40 | Germany | Lung tumors | Linac/NR | n = 49 | None | Median: 19.3 (Range: 6.44– 51.1 with NTC) Median: 12.9 (Range: 4.6–31.3 without NTC) | Normal tissue changes (NTC) | None reported
Ahn et al. (2009)2 | Korea | Stage 1 NSCLC | CyberKnife/NR | n = 8 | None | Range: 5–49 | Tumor response; local control | Mild malaise; mild asymptomatic radiation pneumonitis
Chang et al. (2009)1 | Canada and USA | Unresected pancreatic adenocarcinoma | CyberKnife/NR | n = 77 | Prior: n = 9 RT, n = 15 chemo Concurrent: n = 16 IMRT, n = 59 chemo | Median: 6 (Range: 3–31) Median (Survivors): 12 (Range: 3–31) | Local progression; progression- free survival; overall survival; local control | Grade 2–4 toxicities
Chawla et al. (2009)14 | USA | Adrenal metastases | Novalis/NR | n = 30 3 of 30 also had metastases in the lungs and/or thoracic lymph nodes, liver, or abdominal and/or pelvic lymph nodes | n = 17 prior chemo; n = 9 SBRT | Median: 9.8 (Range: 3.2– 28.3) | Overall survival, survival, distant control, local control, tumor response, pain | Grade 1 nausea, mild fatigue
Choi et al. (2009)16 | Korea | Para-aortic lymph node (PALN) metastases from uterine cervical and corpus cancer | CyberKnife/SBRT planning algorithm | n = 30 | n = 2 prior chemo; n = 9 concurrent chemo | Median: 15 months, Range: 2–65 | Tumor response; overall survival; disease progression-free survival (DPFS); local control; toxicity | Grade 3 or higher toxicity Acute hematologic toxicities of grade 3 or higher during chemo Late toxicity: ureteral stricture
Guckenberger et al. (2009)30 | Germany and Switzerland | Early stage NSCLC and pulmonary metastases | Linac/Collapsed cone dose calculation algorithm | n = 40 | None | Mean: 21, Median: 14, Maximum: 91 - early stage NSCLC Mean: 17, Median: 14, Maximum: 80 - pulmonary metastases | Local control; regional and systemic control for early-stage NSCLC; survival | Pneumonitis grade 2; pneumonitis grade 3; pneumothorax grade 2; pleural effusion grade 2; dyspnea grade 2; esophageal ulceration grade 3
Kawase et al. (2009)50 | Japan | Isolated T1- T2N0M0 primary or metastatic lung tumors | Linac/Collapsed- cone algorithm of Pinnacle3 or the multigrid superposition algorithm of XiO with a density heterogeneity correction | n = 379 | None | Median 29 (Range: 1–72) | Development of extra- pulmonary soft-tissue mass | Co-existing swelling; chest pain; thumb numbness: arm edema
McCammon et al. (2009)65 | USA | Lung and liver tumors | Linac/Pencil-beam algorithm for tissue inhomogeneity correction | n = 141 | None | Median (All): 8.2 (Range: 1.4– 44.4) Median (Survivors): 18.3 Median (Deceased): 5.9 | Tumor response; local control | Grade 2, 3, and 4 events: grade 2, 3, 4 pneumonitis, grade 2 or 3 dermatitis, grade 2 or higher soft tissue/muscle inflammation, fibrosis, vertebral fractions
Milano et al. (2009)66 | USA | Central thoracic lesions | Linac/NR | n = 53 | n = 6 concurrent SBRT boost; n = 9 multiple courses of SBRT (2–3 courses) | Median 10 (Range: <1–78) | Survival; distant progression; local control | Acute grade 1, 2 esophageal toxicity; grade 2 radiation pneumonitis; grades 1–2 hemoptysis; grade 2 pneumonia; grade 3 pneumonia; grade 2 pneumothorax; fatal hemoptysis; grade 3 pericarditis
Milano et al. (2009)68 | USA | Oligometastases | Novalis/NR | n = 77: 42 liver, 21 lung, 5 thoracic lymph nodes, 9 bone n = 13 lung parenchymal and thoracic lymph nodes | 62 of 77: systemic therapy for metastatic disease prior to SBRT 11 of 13 systemic therapy before SBRT | n = 77 Overall Median (n = 77): 23 (Range: 5–85) Living Median (n = 77): 45 (Range: 14–95) Overall Median (n = 13): 21 (Range: 6–66) Living Median (n = 13): 54 (Range: 42–66) | Patterns of recurrence after curative- intent SBRT | NR
Pennathur et al. (2009)79 | USA | Stage NSCLC | Linac/NR | n = 21 | None | Mean: 24 | Tumor response; survival; local progression | Pneumothorax (after fiducial placement)
Ricardi et al. (2009)83 | Italy | Stage 1 NSCLC | Elekta Precise linac/NR | n = 60 | None | Median: 30.9 (Range: 6.7– 56.7) | Radiation- induced lung injury scoring; mean lung dose; normal tissue complication probability | Grade 0–3 pulmonary toxicity
Rusthoven et al. (2009)85 | USA | Metastatic lung cancer | Linac/NR | n = 64 | Prior first-line systemic therapy (cytotoxic chemo and/or molecular targeted therapies) | NR | Progression | NR
Seong et al. (2009)92 | Korea | Hepatocellular carcinoma | CyberKnife/NR | n = 398 | Prior: n = 312 TACE, n = 54 transarterial chemoinfusion (TACI), n = 10 systemic chemotherapy, n = 35 RFA, n = 34 iA- chemotherapy, n = 25 surgery, n = 8 percutaneous ethanol injection, n = 7 holmium | Median: 12 (Range: 0.4–42) | Survival | NR
Stephans et al. (2009)99 | USA | Stage 1 lung cancer | Novalis/NR | n = 92 | None | Median: 18.4 (Range: 1.7–48) | Pulmonary function test; overall survival, local control | Grade 2 radiation pneumonitis
Stephans et al. (2009)100 | USA | Stage 1 NSCLC | Novalis/NR | n = 86 receiving 50 Gy or 60 Gy | None | Overall median: 15.3 (Range: 1.9– 47.6) 50 Gy Median: 19.8 (Range: 1.9– 47.6) 60 Gy Median: 9.5 (Range: 2.1– 19.5) | Local control, nodal failure, distant metastasis, overall survival | Grade 2 radiation pneumonitis; grade 1 or 2 chest wall toxicity
Song et al. (2009)98 | Korea | Stage 1 NSCLC | Linac/NR | n = 32 | None | Median: 26.5 (Range: 5.2–92) | Local tumor control, survival, patterns of failure | Grade 3 severe pulmonary toxicities; 1 death due to bleeding aspiration and pneumonia from SBRT-induced complete bronchial stricture; stricture of lobar bronchus and secondary lung collapse
Takeda et al. (2009)105 | Japan | Primary lung cancer Stage 1A and 1B | Linac/MG- superposition algorithm with heterogeneity correction | n = 63 | None | Median of inoperable patients (n = 49) 31 months (Range: 1–72 months) | Local control; disease-free survival; overall survival; regional recurrence- free; distant metastasis-free; cause-specific survival | Grade 2 or higher radiation pneumonitis; fatal bacterial pneumonia (authors considered SBRT to have possibly contributed to the events leading to death)
Baumann et al. (2008)6 | Sweden, Denmark, Norway | Stage 1 NSCLC | Linac/Pencil beam algorithms with heterogeneity correction | n = 57 | None | Median: 23 (Range: 3–42) | Tumor control; toxicity; lung function and performance status | [underlined: Overall:] grade 1, 2, and 3 toxicity [underlined: Lung-related toxicity:] grade 1–2 cough, grade 3 cough, grade 1–2 dyspnea, grade 3 dyspnea, grade 1–2 pneumonia, grade 3 pneumonia, grade 1–2 pneumonitis, grade 1–2 fibrosis, grade 3 fibrosis, grade 1–2 atelectasis, grade 3 atelectasis, grade 1–2 pleural effusion, grade 3 pleural effusion, grade 1–2 heart disorder, grade 3 heart disorder, grade 1–2 esophagitis [underlined: General toxicity:] grade 1–2 skin, grade 1–2 pain, grade 3 pain, grade 1–2 rib fracture, grade 3 rib fracture, grade 1–2 upper airway infection, grade 1–2 fever, grade 1–2 nausea, grade 1–2 emesis, grade 1–2 fatigue, grade 3 fatigue
Casamassima et al. (2008)12 | Italy | NSCLC or metastases | Elekta Synergy/Pencil beam algorithm for dose calculation | n = 104 | Metastases prior chemo | Median: 13.88 (Range: 1.37– 49.4) | Overall survival (Kaplan-Meier method); tumor response | Acute lung toxicity; dysphagia
Choi et al. (2008)15 | South Korea | Hepatocellular carcinoma | CyberKnife/NR | n = 31 | Prior: n = 17 (TACE, n = 3) percutaneous ethanol injection (PEI, n = 6 RFA) | Median 10.5 (Range: 2–18.5) | Tumor response; survival | [underlined: Treatment-related toxicity]: liver enzymes grade 0, 1, 3; bilirubin grade 0–1; albumin grade 0–1; leukocytes grade 0–2; platelets grade 0, 1, 3; nausea grade 0–1; progression of Child-Pugh classification from A to B
Coon et al. (2008)18 | USA | NSCLC, recurrent disease, or solitary lung metastases | CyberKnife/NR | n = 51 | NR | Median primary and recurrent cancer: 11 (Range: 2–24); Median metastases: 12 (Range: 2–24) | Complete response; partial response; stable disease; disease progression | Grade 2 radiation pneumonitis; exacerbation of preexisting COPD
Fritz et al. (2008)24 | Germany | Stage 1 NSCLC | Elekta Precise Sli/NR | n = 40 | NR | Median: 20 (Range: 6–61.5) | Tumor response as categorized by WHO | Grade 1 radiation dermatitis; grade 1 subcutaneous fibrosis; grade 4 rib fracture
Jereczek-Fossa et al. (2008)45 | Italy | Breast, lung, head and neck, urologic, gynecologic, gastrointestinal, CNS, other primaries | Linac (6–18 MV, used for 3D-CRT and SRT)/NR | n = 108 | Prior radiation doses ranged from 8 to 74.4 Gy (Mean: 37 Gy); n = 95 conventional or 3D-CRT; n = 13 SRT; n = 55 chemo; n = 3 concurrent brachytherapy | Median: 7 (Range: 1–50) | Overall survival; tumor response | No severe toxicity was reported
Kim et al. (2008)51 | South Korea | Pelvic recurrence from rectal carcinoma | CyberKnife/NR | n = 23 | Prior lower anterior resection, abdomino- perineal resection; adjuvant chemo; concurrent chemo- radiotherapy; all salvage chemo before SBRT | Median: 31 (Range: 7–65) | Tumor response; local failure | Nausea, vomiting, pain (Grade 1 & 2; grade 3 & 4 reported; rectal perforation
Kunos et al. (2008)57 | USA | Squamous cell carcinoma of the vulva | CyberKnife/NR | n = 3 | n = 3 prior pelvic radiation for vulvar cancer | At least 2 | Tumor response | No skin, urinary, or gastrointestinal toxicities were observed during course
Lagerwaard et al. (2008)58 | The Netherlands | Stage 1 NSCLC | Linac/NR | n = 206 | Prior: n = 7 pneumonectomy, n = 2 bilobectomy, n = 17 lobectomy, n = 2 wedge resection, n = 3 chemoradio- therapy, n = 5 radiotherapy, n = 1 endobronchial therapy | Median 12 (Range: 3–44) | Overall survival; disease-free progression; local failure; regional failure; distance progression- free survival | Fatal cerebrovascular accident during treatment; fatigue, local chest wall pain; nausea; dyspnea; cough; grade 3 or greater pneumonitis; rib fractures; chronic thoracic pain syndromes
Norihisa et al. (2008)71 | Japan | Oligometastatic lung tumors | Linac/NR | n = 34 | Most prior surgical resection and chemo for primary cancer | Median 27 (Range: 10–80) | Overall survival rate; local relapse free rate; progression- free rate; disease free interval; local response | Pulmonary toxicity (grade 1 and 2): cough, hemoptysis, dyspnea, pleural effusion, radiographic changes, bacterial pneumonia, grade 3 pulmonary toxicity, grade 1 skin toxicity with faint erythema or pigmentation, skin ulcer Musculoskeletal: bone fracture of the rib, chest wall pain, mild pain, grade pericardial effusion, temporal liver dysfunction
Onimaru et al. (2008)76 | Japan | NSCLC | NR/treatment planning made with Focus or Xio calculation algorithm: 31 Clarkson, 10 Superposition | n = 41 | None | Median: 27 (Range: 9–62) | Overall actuarial survival and cause-specific survival (Kaplan- Meier); deaths from causes other than lung cancer; local control rate | Radiation pneumonitis; pleural effusion; chest wall pain from radiation pleuritis
Svedman et al. (2008)104 | Sweden and Italy | Primary or metastatic renal disease | Linac/Pencil beam algorithm (dose planning) | n = 7 | n = 1 prior metastatic surgery; n = 1 prior interferon- alpha | Maximum 70 | Creatinine levels; local control; kidney function | Grade 1–2: nausea, fatigue, local pain
Brown et al. (2007)10 | USA | Stage 1 NSCLC and lung metastases | CyberKnife/NR | n = 88 | n = 7 prior conventional fractionated external radiotherapy | Range: 1–36 | Complete response; partial response; stable disease; progression of disease | Lung and esophagus toxicity, radiation pneumonitis; esophagitis; mild fatigue
Guckenberger et al. (2007)29 | Switzerland | NSCLC or pulmonary metastatic lesions | NR/NR | n = 70 | NR | Median: 16 (Range: 1.5–85) | Actuarial local tumor control; complete response | Symptomatic pneumonitis; mild cough or dyspnea not requiring steroids; grade 2 pneumonitis; pleural effusion
Teh et al. (2007)107 | USA | Spine, bone, soft tissue/organ, and lymph node | Novalis/NR | n = 80 | Prior RT; n = 1 prior surgery for sacral nerve neuroma | NR | Pain relief; symptom control; tumor response | NR
Baumann et al. (2006)5 | Sweden | Stage 1 NSCLC | Linac/NR | n = 141 | None | Median: 33 (Range: 1–107) | Tumor response - complete response; partial response; stable disease; local failure | Mild toxicity; skin rash; costal fracture; cough; radiological pneumonitis/fibrosis; atelectasis; grade 3–4 toxicity
Joyner et al. (2006)47 | USA | Metastases or Recurrence NSCLC | Linac/NR | n = 9 | None | Median: 10.6 (Range: 2.5– 42.5) | Overall survival; local tumor control; normal tissue imaging changes | Transient pneumonitis; fibrotic reactions; some degree of wall thickening; lobe atelectasis; narrowing of lobe bronchus
Paludan et al. (2006)78 | Denmark | Stage 1 NSCLC | NR/DVH parameters calculated by use of a pencil beam algorithm | n = 28 | None | Median: 6.7 (Range: 2.1–7.5) | Dyspnea development | NR
Sinha et al. (2006)95 | USA | Bilateral primary lung cancer | NR/NR | n = 10 | n = 1 prior resection of lesion | Mean: 20.7, Median: 18.5 (Range: 7–42) | Tumor response | Grade 1 and 2 complications
Beitler et al. (2004)7 | USA | Renal cell carcinoma | NR/NR | n = 9 | n = 1 prior nephrectomy | Median: 26.7 | Survival calculated by Kaplan-Meier method | Nausea, vomiting, glandular atypia in the stomach
Gunven et al. (2003)32 | Sweden | Recurring liver metastases of colorectal cancer | Linac/NR | n = 4 | Prior surgical resection | 10–101 | Tumor sizes and evolution; tumor regression | Epigastric pain; slight diffuse mucosal redness

* Author’s retrospectively reviewed two case series: patients treated with SBRT (February 2004 – May 2007) and patients treated with surgery (January 2000 – December 2006)

† Author’s retrospectively reviewed two case series: patients treated with SBRT or wedge resection (February 2003 – February 2009)

3D-CRT: Three-dimensional conformal radiation therapy

CNS: Central nervous system

COPD: Chronic obstructive pulmonary disease

DPFS: Disease progression-free survival

DVH: Dose volume histogram

Gy: Gray

IMRT: Intensity modulated radiation therapy

NSCLC: Non-small cell lung cancer

NR: Not reported

NTC: Normal tissue changes

PALN: Para-aortic lymph nodes

PSA: Prostate specific antigen

RFA: Radiofrequency ablation

RT: Radiation therapy

SBRT: Stereotactic body radiation therapy

SRT: Stereotactic radiotherapy

TACE: Transcatheter arterial chemoembolization

TACI: Transarterial chemoinfusion

WHO: World Health Organization

WPRT: Whole pelvic radiation therapy