# Ongoing Clinical Trials

Ongoing Clinical Trials

Condition | ClinicalTrials.gov Identifier | Study Design | Intervention | Primary Outcome Measures | Secondary Outcome Measures | Estimated Enrollment | Planned Duration | Location
Breast Cancer, Metastatic | NCT00167414 | Nonrandomized; historical control | HSBRT | OS, DFS | CRR, chemical and radiobiological response, QoL | 80 | December 2000– Ongoing | Rochester, NY
Cholangiocarcinoma Klatskin Tumor Biliary Tract Cancer | NCT00630890 | Single group | External beam radiation and CyberKnife radiosurgery boost and capecitabine | Acute toxicities, MTD | LC, radiographic response, delayed and long-term toxicities, DSS, OS | 11 | October 2007– October 2011 | San Francisco, CA
Cholangiocarcinoma | NCT00983541 | Single group | SBRT, brachytherapy, fluorouracil (5-FU), gemcitabine | Toxicity | OS, PFS, tumor response, LC, rate of distant mets | 12 | September 2009– September 2011 | Salt Lake City, UT
Colorectal Cancer (fewer than 5 metastases) | NCT00807313 | Single group | SBRT | Metabolic complete remission rate | Toxicity, PFS, LC, OS | 81 | December 2008– Ongoing | Brussels, Belgium
Hepatocellular Carcinoma | NCT00746655 | Single group | SBRT with TACE | Feasibility and toxicity | LC, RC, HRQoL | 12 | July 2009– Ongoing | University of Pittsburgh, Pittsburgh, PA
Hepatocellular Carcinoma | NCT00914355 | Single group | SBRT | Local PFS | PFS, OS, QoL, toxicity, cytokine response | 47 | August 2007– August 2010 | Toronto, Canada
Hepatocellular Carcinoma | NCT00243841 | Nonrandomized | SBRT | 6 month LC | Not specified | 60 | May 2004– December 2015 | Indianapolis, IN
Hepatocellular Carcinoma | NCT01020812 | Single group | SBRT with TACE | Efficacy, toxicity | PFS, OS, correlate tumor marker alpha-fetoprotein (AFP) with tumor response and survival | 24 | September 2009– September 2013 | Stanford, CA
Kidney Cancer | NCT00445757 | Single group | Conventional surgery; neoadjuvant therapy; SRS | MTD, toxicity | DFS, LP, DF, DSS | 20 | January 2007– January 2012 | Cleveland, OH
Kidney Cancer | NCT00458484 | Single group | SRS | MTD | OS, DFS, LP, DF | 32 | February 2007– February 2012 | Cleveland, OH
Liver Cancer | NCT01030757 | Single group | SBRT with Tomotherapy | Tumor response | Toxicity, PFS, OS | 43 | June 2009– January 2014 | Albuquerque, NM
Liver Cancer | NCT00607828 | Single group | SBRT | Toxicity, MTD | Not specified | 28 | November 2007– October 2009 | Omaha, NE
Liver Cancer | NCT00777894 | Single group | SBRT; Three- dimensional RT; IMRT | Dose limiting toxicity; objective response | Adverse events, tumor response, PFS, OS, Child- Pugh Score | 73 | November 2008– March 2012 | Haifa, Israel; Jerusalem, Israel; Masstricht, Netherlands; Aarau, Switzerland; Zurich, Switzerland; Bellinzona; Switzerland; Bern, Switzerland; St. Gallen, Switzerland; Basel, Switzerland
Liver Cancer | NCT00607828^1^ | Single group | SBRT | Toxicity, MTD | NS | 28 | November 2007– October 2009 | Omaha, NE
Liver Metastases | NCT00914615 | Single group | SBRT | Local PFS | PFS, OS, QoL, toxicity, cytokine response | 17 | August 2007– August 2010 | Toronto, Canada
Liver Metastases | NCT00938457 | Single group | SBRT | MTD, minimum effective dose | Adverse events, toxicity, tumor response, LC, time to progression, blood chemistry and hepatic function | 60 | July 2009– November 2017 | Rochester, MN
Primary and Metastatic Liver Tumors | NCT00691691 | Single group | SBRT | CRR | Toxicity | 71 | November 2007– November 2008 | Calgary, Alberta, Canada
Liver Metastases | NCT00567970^1^ | Single group | SBRT | MTD | Toxicity; adverse events; QoL; Response; physical exam results | 18 | April 2007– October 2008 | Jacksonville, FL
Liver Metastases | NCT00547677 | Single group | SBRT | Toxicity | Tumor response | 27 | July 2004– December 2007 | Dallas, TX; Minneapolis, MN
Lung and Liver Tumors | NCT00178477^1^ | Single group | SBRT | NS | NS | 48 | January 2002– January 2006 | Rochester, NY
Lung Tumors | NCT00632281 | Single group | SBRT | Disease status | Toxicity | 750 | January 2006– Ongoing | University of Florida, Gainesville, FL
Lung Tumors | NCT00832780 | Single group | SBRT using Tomotherapy | CRR (complete and partial) | | 45 | January 2008– October 2011 | University of New Mexico, Albuquerque, NM
Lung Cancer | NCT00238602 | Single group | SRS (CyberKnife) | MTD, symptoms and radiographic responses | NR | 60 | March 2000– Ongoing | Stanford, CA
Lung Cancer | NCT00687986 | Randomized | SRT vs. Primary Resection | LC, RC, QoL; treatment costs | OS; QALY; total costs | 960 | August 2008– December 2013 | Amsterdam, Netherlands
Lung Cancer | NCT01051037 | Single group | SBRT and radiofrequency ablation | Toxicity | One year LC, PFS, OS | 35 | January 2010– January 2013 | Los Angeles, CA
Non-small Cell Lung Cancer | NCT00643318 | Single group | CyberKnife SRS | CRR, LCR, PFS, OS | QoL, procedures related outcomes | 156 | April 2006– July 2013 | Pittsburgh, PA
Non-small Cell Lung Cancer | NCT00870116 | 3-group comparison (nonrandomized) | SBRT (CyberKnife) vs. SBRT (linac) vs. Conformational RT | LC | Economic, QoL, PFS, OS | 120 | April 2009– March 2013 | Multiple centers, France
Non-small Cell Lung Cancer | NCT00551369 | Single group | SBRT followed by surgical resection in patients with progression | LC | Toxicity, LC, RC, DFS, OS | 33 | December 2007– June 2012 | Multicenter, U.S. and Canada
Non-small Cell Lung Cancer | NCT00843726 | Randomized | SBRT—one vs. three fractions | Toxicity, OS | NS | 98 | September 2008– April 2013 | Roswell Park Cancer Institute, New York, NY
Non-small Cell Lung Cancer | NCT00087438^2^ | Single group | SBRT | LC | RC, DFS, OS | 52 | May 2004– March 2009 | University of Rochester, Rochester, NY
Non-small Cell Lung Cancer | NCT00547105 | Single group | Erlotinib hydrochloride and SBRT | PFS | Disease progression, Toxicity, OS | 24 | June 2007– June 2010 | University of Texas, Dallas, TX
Non-small Cell Lung Cancer | NCT00238875 | Single group | SBRT | OS at 3 years | RFS, Toxicity, PFS, OS | 167 | July 2004– November 2011 | Multiple sites, Japan
Non-small Cell Lung Cancer | NCT00591838 | Single group | SBRT | Toxicity | LC, RC, DFS, OS | 45 | August 2006– August 2016 | Washington University Hospital, St. Louis, MO
Non-small Cell Lung Cancer | NCT00727350 | Single group, historical control | SBRT | Toxicity | LC, OS, DFS, PFS, QoL | 44 | March 2007– December 2012 | Brussels, Belgium
Non-small Cell Lung Cancer (Stage I, Stage II, or peripheral lung recurrence) | NCT00489008 | Three uncontrolled groups | SBRT | DFS, OS | Not reported | 138 | November 2005– September 2012 | M.D. Anderson Cancer Center, Houston, TX
Non-small Cell Lung Cancer | NCT00750269 | Single group | SBRT | Toxicity | LC, PFS, OS | 94 | February 2009– May 2012 | Multiple sites, U.S. and Canada
Non-small Cell Lung Cancer | NCT00840749 | Randomized, open label | SBRT vs. surgical resection | OS | DSS, PFS, Toxicity | 1,030 | December 2008– December 2013 | Multiple sites, U.S. and China
Non-small Cell Lung Cancer | NCT00246181^1^ | Single group | SBRT | Dosage | Efficacy | 117 | December 1999– December 2009 | Indianapolis, IN
Pancreatic Neoplasms | NCT00833859 | Single group | SBRT and Gemcitabine, Docetaxel and Capecitabine | Rate of surgical resection with negative margins | Toxicity, OS | 24 | March 2009– March 2012 | Tampa, FL
Pancreatic Cancer | NCT00350142^1^ | Single group, historical control | SBRT | OS, QoL | NS | 40 | December 2004– October 2008 (completed) | Stanford University, Stanford, CA
Pancreatic Cancer | NCT00425841 | Single group | Gemcitabine hydrochloride, oxaliplatin, adjuvant therapy, hypofractionated radiation therapy, neoadjuvant therapy, SRS | CRR | Toxicity, time to progression, time to death, tumor response | 29 | May 2006–NS^1^ | Munich, Germany
Pancreatic Cancer | NCT01068327 | Single group | SBRT, gemcitabine hydrochloride, leucovorin calcium, fluorouracil, nelfinavir mesylate; conventional surgery | Dose limiting toxicity, MTD | Tumor response; | 24 | November 2007– December 2012 | Omaha, NE
Pancreatic Cancer | NCT01025882 | Single group | SBRT, gemcitabine hydrochloride, pancreato- duodenectomy | Toxicity, morbidity, tumor response, length of hospital stay | NS | 30 | October 2009– October 2014 | Dallas, TX
Prostate Cancer | NCT00643617 | Single group | CyberKnife SRS | Biochemical DFS, rates of acute and late gastro- intestinal and genitourinary toxicities | LF, DF, DFS, DSS, OS, QoL | 253 | November 2007– January 2014 | San Diego, CA; Fresno, CA; Great Falls, MT; Oklahoma City, OK; Tyler, TX
Prostate Cancer | NCT00619515 | Single group | SRS | Rate of acute toxicities | Rate of late grade 3–5 toxicities, DFS, OS, LF, DF, QoL | 102 | December 2007– December 2009 | Cleveland, OH; Chardnor, OH; Mentor, OH; Canton, OH; South Euclid, OH; Orange Village, OH; Westlake, OH; Middleburgh Heights; OH
Prostate Cancer | NCT00643994 | Single group | CyberKnife SRS | Rates of acute and late grade 3–5 gastro- intestinal and genitourinary toxicities, rate of biochemical DFS | LF, DF, DFS, DSS, OS, QoL | 298 | December 2007– January 2014 | Jupiter, FL; Arlington Heights, IL; Lexington, KY; Boston, MA; Ann Arbor, MI; Trenton, NJ; Seattle, WA
Prostate Cancer | NCT00941915 | Single group | SBRT with continuous real- time evaluation of prostate motion and IMRT for plan reoptimization based on “anatomy of the day” | Toxicity | DFS, QoL | 60 | September 2009– December 2012 | Duke University, Durham, NC
Prostate Cancer | NCT00547339 | Single group | SBRT | Toxicity | OS, LC, RC, DSS | 97 | July 2006– October 2010 | University of Texas, Dallas, TX
Prostate Cancer | NCT01059513 | Single group | SBRT | Long term toxicities; tumor control | Not specified | 60 | January 2010– January 2017 | Los Angeles, CA
Unspecified Adult Solid Tumor | NCT00311597 | Single group | SRS | MTD, MD | Radiographic response rate, median time to progression, toxicity, cause of death | 48 | June 2002– Ongoing | Winston-Salem, NC
Extracranial Recurrent, Metastatic Cancer or Primary Tumors | NCT00006456^1^ | Single group | SRS | NR | NR | 10–25 within 2–3 years | February 1999– Ongoing | Richmond, VA

1 Although the estimated completion date has expired, the trial is still ongoing and “active” according to ClinicalTrials.gov at the time of this report.

2 This study has been completed and results have been published. See Appendix L. Literature Results.109

CRR: Clinical response rate

DF: Distant failure

DFS: Disease-free survival

DSS: Disease-specific survival

HRQoL: Health-related quality of life

HSBRT: Hypofractionated stereotactic body radiotherapy

IMRT: Intensity modulated radiation therapy

LC: Local control

LCR: Local control rate

LF: Local failure

LP: Local progression

M: Male

MD: Minimum dose

MTD: Maximum tolerated dose

NS: Not specified

OS: Overall survival

PFS: Progression-free survival

QALY: Quality-adjusted life years

QoL: Quality of life

RC: Regional control

RT: Radiation therapy

SBRT: Stereotactic body radiation therapy

SRS: Stereotactic radiosurgery

TACE: Transcatheter arterial chemoembolization