# Facilities Performing SBRT for Solid Tumors

Facilities (Information updated September 2009)

Hospital Name | State | City | Device(s) | Treatment Site(s)
St. Vincent’s Medical Center | AK | Little Rock | Novalis TX | NS
CyberKnife of Birmingham | AL | Birmingham | CyberKnife | Colon, Kidney, Lung, Ovaries, Pancreas, Prostate, Uterus
Gulf Coast Cancer Centers | AL | Foley | Novalis | Liver mets, Lung
University of Alabama Hospital | AL | Birmingham | Tomotherapy | Prostate
University of Southern Alabama | AL | Mobile | CyberKnife | NS
Banner Good Samaritan Med Center | AZ | Phoenix | Tomotherapy, Novalis TX | NS
Mayo Clinic Hospital | AZ | Phoenix | NR | NS
Scottsdale Healthcare-Osborn | AZ | Scottsdale | Novalis | Breast, Liver, Lung, Pancreas, Prostate, Rectal
Scottsdale Healthcare-Shea | AZ | Scottsdale | Novalis | Breast, Liver, Lung, Pancreas, Prostate, Rectum
St. Joseph’s/Carondolette | AZ | Tucson | Novalis TX | NS
St. Joseph’s Hospital and Med Center | AZ | Phoenix | CyberKnife | Abdomen, Chest
University Medical Center | AZ | Tucson | Novalis | Liver and other extracranial locations
Cedars-Sinai Medical Center | CA | Los Angeles | NR | Lung
City of Hope National Medical Center | CA | Duarte | Tomotherapy | Lung, Prostate
Community Reg MC/CA Cancer Center | CA | Fresno | CyberKnife | Liver, Lung, Pancreas, Pelvis, Prostate
Comprehensive Blood and Cancer Center | CA | Bakersfield | CyberKnife | NS
CyberKnife Centers of San Diego, Inc. Ruffin | CA | San Diego | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
CyberKnife Centers of San Diego, Inc., Encinitas | CA | Encinitas | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
CyberKnife of Southern California at Vista | CA | Vista | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
Eisenhower Medical Center | CA | Rancho Mirage | Novalis TX | Prostate
El Camino Hospital | CA | Mountain View | Novalis | NS
Hoag Memorial Hospital Presbyterian | CA | Newport Beach | Tomotherapy | Liver Mets, Lung Mets
John Muir Medical Center, Walnut Creek | CA | Walnut Creek | Novalis | Breast, Colon, Liver, Liver Mets, Lung Mets, Prostate
Kaiser Permanente | CA | San Francisco | CyberKnife | NS
Kaiser – Roseville | CA | Roseville | Novalis TX | NS
Long Beach Memorial Medical Center | CA | Long Beach | Tomotherapy | Pelvis, Prostate
Miller Children’s Hospital | CA | Long Beach | Tomotherapy | NS
Newport Diagnostic Center | CA | Newport Beach | CyberKnife | Prostate (pending)
Palo Alto Medical Center | CA | Palo Alto | Novalis TX | NS
Palomar Hospital | CA | Escondido | Novalis TX | NS
Pomona Valley Hospital Medical Center | CA | Pomona | Trilogy | Prostate and other extracranial sites
Saint Agnes Medical Center | CA | Fresno | Novalis | NS
Santa Barbara Hospital | CA | Santa Barbara | Novalis TX | NS
Select Healthcare (Orange County Memorial) | CA | Fountain Valley | CyberKnife | Liver, Lung
Sharp Grossmont Hospital | CA | La Mesa | Tomotherapy, Novalis | Prostate and other extracranial sites
Sharp Memorial Hospital | CA | San Diego | Novalis | Prostate and other extracranial sites
St. Bernardine Medical Center | CA | San Bernardino | Tomotherapy | Prostate and other extracranial sites
St. Joseph Hospital | CA | Orange | Trilogy | NS
Stanford Hospital and Clinics | CA | Palo Alto | CyberKnife (2) | Liver, Lung, Pancreas, Prostate
UCLA | CA | Los Angeles | Novalis TX | NS
UCSF Medical Center | CA | San Francisco | CyberKnife | Lung, Pancreas, Prostate
Univ of CA San Diego Medical Center | CA | San Diego | Trilogy | NS
Univ of CA, Davis Medical Center | CA | Sacramento | Novalis | NS
Univ of CA, Irvine Medical Center | CA | Orange | Trilogy | NS
Boulder Community Hospital | CO | Boulder | CyberKnife | NS
Denver CyberKnife Center | CO | Lone Tree | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
Penrose Hospital | CO | Colorado Springs | CyberKnife | Liver, Lung, Pancreas, Prostate
Poudre Valley Hospital | CO | Fort Collins | NR | NS
Rocky Mountain Cancer Center | CO | Aurora | Novalis TX | NS
Rocky Mountain CyberKnife | CO | Boulder | CyberKnife | Liver, Lung, Musculoskeletal, Pancreas, Prostate
University of CO Hospital/Anschutz Cancer Pavilion | CO | Aurora | Novalis | NS
St. Anthony’s Hospital | CO | Denver | Novalis TX | NS
Cyberknife Center at St. Francis | CT | Hartford | CyberKnife | Liver, Lung, Pancreas, Prostate
CyberKnife Center at Stamford Hospital | CT | Stamford | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
Hartford Hospital | CT | Hartford | Trilogy | NS
Hospital of Central CT | CT | New Britain | Novalis | Lung, Prostate
Yale University | CT | New Haven | Novalis TX | NS
Hospital of Saint Raphael | CT | New Haven | CyberKnife | Liver, Lung, Pancreas, Prostate
Georgetown University Hospital –MedStar Health | DC | Washington | CyberKnife | Kidney, Liver, Lung
Washington Hospital Center | DC | Washington | Trilogy | NS
Christiana Hospital | DE | Newark | CyberKnife | Liver, Lung, Pancreas, Pelvis, Prostate
Baptist Hospital of Miami | FL | Miami | Tomotherapy | Bone, Breast, Lung, Prostate
Baptist Hospital/University of Northern FL | FL | Jacksonville | Novalis TX | NS
Bethesda Memorial Hospital | FL | Boynton Beach | Trilogy | Kidney, Liver, Lung, Pancreas
Blake Medical Center | FL | Bradenton | CyberKnife | Spine
Boca Raton Community Hospital | FL | Boca Raton | Novalis TX | NS
Brandon Regional Hospital HCA | FL | Brandon | CyberKnife | Bile Duct, Bone, Colon/rectum, Kidney, Liver, Lung, Lymph node, Pancreas, Prostate
Broward General Medical Center | FL | Fort Lauderdale | CyberKnife, Trilogy | Liver, Lung, Pancreas
Cancer Care Centers of Brevard | FL | Melbourne | CyberKnife | Kidney, Liver, Lung, Pancreas, Pelvic Organs, Prostate, Skin
Capital Regional Medical Center | FL | Tallahassee | Tomotherapy | Prostate
Coastal CyberKnife and Radiation Oncology | FL | Fort Pierce | CyberKnife | NS
CyberKnife Cancer Center | FL | Jacksonville | CyberKnife | Liver (primary and mets), Pancreas, Prostate
CyberKnife Center of Miami | FL | Miami | CyberKnife | Bladder, Breast, Gynecologic, Liver, Lung, Pancreas, Prostate
CyberKnife Center of Palm Beach | FL | Palm Beach Gardens | CyberKnife | Liver, Lung, Pancreas, Prostate
CyberKnife Center of Tampa Bay | FL | Tampa | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
Doctors Hospital | FL | Coral Gables | Tomotherapy | Bone, Breast, Lung, Prostate
Florida Hospital | FL | Orlando | Trilogy | NS
H. Lee Moffitt Cancer Center | FL | Tampa | Tomotherapy, Novalis | NS
HCA Central Florida | FL | Sanford | CyberKnife | Kidney, Liver, Lung, Pancreas, Pelvis, Prostate
Jackson Health System | FL | Miami | CyberKnife | Breast
Jupiter Medical Center | FL | Jupiter | CyberKnife, Trilogy | NS
Martin Memorial Hospital | FL | Stuart | Novalis TX | NS
Mayo Clinic Jacksonville | FL | Jacksonville | NR | NS
M.D. Anderson Cancer Center/Orlando | FL | Orlando | Novalis | Lung
Melbourne Internal Medicine Associates | FL | Melbourne | Novalis TX | NS
Memorial Hospital of Jacksonville | FL | Jacksonville | CyberKnife | Liver, Lung, Pancreas, Prostate
Mount Sinai Medical Center | FL | Miami Beach | Trilogy | NS
New Millenium CyberKnife | FL | Brandon | CyberKnife | NS
North Broward Medical Center | FL | Deerfield Beach | CyberKnife, Trilogy | Liver, Lung, Pancreas
North Florida Regional Medical Center | FL | Gainesville | CyberKnife | Liver, Lung, Pancreas, Pelvis, Prostate
Orlando Regional Medical Center | FL | Orlando | Tomotherapy, Novalis | Liver, Lung
Sacred Heart Hospital of Pensacola | FL | Pensacola | Trilogy | NS
Shands at the University of Florida | FL | Gainesville | Trilogy | NS
South Miami Hospital | FL | Miami | Tomotherapy | NS
University of Florida | FL | Gainesville | Triology TX | NS
Wellington Regional Medical Center | FL | Wellington | Novalis | NS
Emory Crawford Long Hospital | GA | Atlanta | Trilogy | NS
Emory University | GA | Atlanta | Trilogy TX | NS
Fannin Regional Hospital | GA | Blue Ridge | NR | NS
Medical College of Georgia Health | GA | Augusta | Trilogy | NS
Memorial Health | GA | Savannah | Trilogy | NS
Piedmont Hospital | GA | Atlanta | Trilogy | NS
South Georgia Medical Center | GA | Valdosta | Synergy | NS
Wellstar Kennestone Hospital | GA | Marietta | CyberKnife | NS
Clarinda Regional Health Center | IA | Clarinda | Novalis | NS
CyberKnife Radiosurgery Center of Iowa | IA | Des Moines | CyberKnife | Liver, Lung
Mercy Medical Center | IA | Cedar Rapids | Tomotherapy | Prostate
Mercy Medical Center-Des Moines | IA | Des Moines | NR | Spine
Saint Alphonsus Regional Medical Center | ID | Boise | Novalis | Liver, Lung, Prostate
Advocate Christ Medical Center | IL | Oak Lawn | CyberKnife | Lung, Pancreas, Prostate
Advocate Good Samaritan Hospital | IL | Downers Grove | CyberKnife | Liver, Lung, Pancreas, Prostate
Advocate Lutheran General Hospital | IL | Park Ridge | Tomotherapy | Bone Mets, Gynecologic, Pancreas, Prostate
CyberKnife Service at Community Cancer Center | IL | Normal | CyberKnife | NS
Edward Hospital | IL | Naperville | Trilogy | Lung, Prostate
Elmhurst Memorial Hospital | IL | Elmhurst | CyberKnife | Liver, Lung, Pancreas, Prostate
Evanston Hospital | IL | Evanston | Novalis | Breast, Liver, Lung, Prostate
Loyola University Medical Center | IL | Maywood | Novalis | NS
Northwest Community Hospital | IL | Arlington Heights | CyberKnife | Liver, Lung, Pancreas, Prostate
OSF Saint Francis Medical Center | IL | Peoria | Trilogy | NS
Provena Saint Joseph Hospital | IL | Elgin | Trilogy | NS
Provena Saint Joseph Medical Center | IL | Joliet | Trilogy | NS
Rush University Medical Center | IL | Chicago | Tomotherapy | Prostate
Saint Joseph Hospital | IL | Chicago | Tomotherapy | NS
Univ of IL Medical Center at Chicago | IL | Chicago | Trilogy | Metastatic treatment
University of Chicago Medical Center | IL | Chicago | Trilogy | Metastatic treatment
Clarian Health Partners | IN | Indianapolis | Novalis | NS
Community Hospital | IN | Munster | CyberKnife, Trilogy | Liver, Lung, Pancreas
CyberKnife Center St. Catherine Hospital | IN | East Chicago | CyberKnife | Liver Mets, Lung, Pancreas
CyberKnife of Indianapolis | IN | Indianapolis | CyberKnife | Liver, Lung, Pancreas, Pelvis, Prostate
Goshen General Hospital | IN | Goshen | Tomotherapy, Trilogy | Breast, Colon, Liver, Lung, Prostate
Memorial Hospital of South Bend | IN | South Bend | Trilogy | NS
Methodist Hospitals | IN | Gary | NR | Lung Mets
Parkview Health | IN | Fort Wayne | CyberKnife | Liver, Lung, Pancreas, Pelvis
St. Mary’s Medical Center of Evansville | IN | Evansville | Novalis, Tomotherapy | NS
St. Vincent Indianapolis Hospital | IN | Indianapolis | Novalis | Liver, Lung, and Prostate
St. Vincent Jennings Hospital | IN | North Vernon | Novalis | Liver, Lung, and Prostate
St. Vincent Randolph Hospital | IN | Winchester | Novalis | Liver, Lung, and Prostate
Menorah Medical Center | KS | Overland Park | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
Providence Medical Center | KS | Kansas City | Trilogy | Liver, Lung, Pancreas
University of Kansas Hospital | KS | Kansas City | Novalis | NS
Via Christi Regional Medical Center | KS | Wichita | CyberKnife | NS
Baptist Hospital East | KY | Louisville | Novalis | Liver, Lung, Prostate
Central Baptist Hospital | KY | Lexington | CyberKnife | NS
CyberKnife Ctr W. Jefferson Med Center | LA | Marrero | CyberKnife | Liver, Lung, Pancreas
CyberKnife of Louisiana | LA | Lafayette | CyberKnife | Liver, Lung, Pancreas, Prostate, Skeletal
East Jefferson Hospital | LA | Metairie | Novalis TX | NS
Mary Bird Perkins Cancer Center | LA | Baton Rouge | Tomotherapy, Novalis | Prostate, Liver
Rapides Regional Medical Center | LA | Alexandria | Trilogy | NS
Slidell Memorial Hospital | LA | Slidell | Trilogy | NS
Baystate Medical center | MA | Springfield | NR | NS
Beth Israel Deaconess Medical Center | MA | Boston | CyberKnife | Liver, Lung, Pancreas, Prostate
Boston Medical Center | MA | Boston | CyberKnife | Liver, Lung, Pancreas, Prostate
Brigham and Women’s Hospital | MA | Boston | NR | Lung, Prostate
Brigham and Women’s/Harvard | MA | Boston | Novalis TX | NS
Dana Farber Cancer Institute | MA | Boston | Novalis | NS
Children’s Hospital Boston | MA | Boston | Novalis | NS
Lahey Clinic Hospital | MA | Burlington | Trilogy | Liver, Lung, Pancreas
Lowell General Hospital | MA | Lowell | Synergy | Prostate
Massachusetts General Hospital | MA | Boston | NR | NS
Mercy Medical Center | MA | Springfield | Synergy | NS
Milford Regional Medical Center | MA | Milford | NR | NS
New England Medical Center | MA | Boston | Axesse | Liver Mets, Lung, Prostate
Northshore Medical Center | MA | Peabody | Novalis TX | NS
St. Ann’s Hospital | MA | Fall River | Novalis TX | NS
UMass Memorial Medical Center | MA | Worcester | NR | NS
Anne Arundel Medical Center | MD | Annapolis | Novalis | Liver, Lung, Prostate
Baltimore Washington Medical Center | MD | Glen Burnie | NR | Lung, Nasal, Skeletal Mets
Franklin Square Hospital Center | MD | Baltimore | CyberKnife | Lung
Frederick Memorial Hospital | MD | Frederick | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate, Skeletal Mets
Johns Hopkins Hospital | MD | Baltimore | Tomotherapy | Prostate
Maryland Regional Cancer Care | MD | Rockville | Novalis | Liver, Lung, Prostate
Peninsula Regional Health System | MD | Salisbury | Trilogy | NS
Sinai Hospital of Baltimore | MD | Baltimore | CyberKnife (2) | Liver, Lung, Pancreas, Prostate
St. Agnes HealthCare | MD | Baltimore | Tomotherapy | NS
University of Maryland Medical Center | MD | Baltimore | Trilogy | NS
York Hospital | ME | York | Trilogy | NS
Bay Regional Medical Center | MI | Bay City | Tomotherapy | NS
Beaumont Hospital - Royal Oak | MI | Royal Oak | Synergy | Breast, Lung, Pancreas, Prostate
Henry Ford – Downriver | MI | Trenton | Trilogy TX | NS
Henry Ford Hospital | MI | Detroit | Trilogy TX, Novalis | Adrenal, Liver, Lung, Pancreas
Henry Ford Hospital – WBC | MI | West Bloomfield Campus | Novalis TX | NS
Karmanos Cancer Center | MI | Detroit | Tomotherapy | Lung, Prostate
Lemme Holton Cancer Center | MI | Grand Rapids | Novalis TX
McLaren Regional Medical Center | MI | Flint | Tomotherapy | NS
MidMichigan Medical Center-Midland | MI | Midland | NR | Kidney, Liver, Lung Mets, Prostate
North Oakland Medical Centers | MI | Pontiac | Tomotherapy | NS
Oakwood Hospital/Med Center | MI | Dearborn | NR | Adrenal, Kidney, Liver, Lung, Pelvis
Saint Mary’s Health Care | MI | Grand Rapids | Tomotherapy | NS
Sparrow Health System | MI | Lansing | Tomotherapy | NS
Spectrum Health | MI | Grand Rapids | Novalis | NS
St. Joseph Mercy | MI | Ann Arbor | CyberKnife | Liver, Lung, Pancreas, Prostate
St. Mary’s of Michigan | MI | Saginaw | CyberKnife, Tomotherapy | Liver, Lung, Pancreas, Prostate
Abbott Northwestern Hospital | MN | Minneapolis | Trilogy | Pancreas
Park Nicollet Health – Frauenshuh Cancer Ctr | MN | St. Louis Park | Novalis | Liver, Lung, Pancreas
St. Cloud Hospital | MN | Saint Cloud | Synergy | NS
St. Joseph’s Hospital | MN | Saint Paul | CyberKnife | Kidney, Liver, Lung, Pancreas, Pelvis, Prostate
St. Luke’s Hospital | MN | Duluth | NR | NS
Barnes-Jewish Hospital | MO | Saint Louis | NR | Gynecologic, Lung Mets
Ellis Fischel Cancer Center | MO | Columbia | Trilogy | NS
Lake Saint Louis Oncology/SLU Hospital | MO | Saint Louis | CyberKnife | Liver, Lung, Pancreas, Prostate
Mercy Saint John’s Cancer Center | MO | Springfield | CyberKnife | Liver, Lung, Pancreas
Research Medical Center | MO | Kansas City | NR | Liver, Pancreas
Saint Francis Medical Center | MO | Cape Girardeau | NR | NS
Saint Louis University Hospital | MO | Saint Louis | CyberKnife | Liver, Lung, Pancreas, Prostate
Saint Luke’s Hospital of Kansas City | MO | Kansas City | Novalis | NS
Southeast Missouri Hospital | MO | Cape Girardeau | Novalis | NS
SSM DePaul Health Center | MO | Bridgeton | Tomotherapy | NS
St. Anthony’s Medical Center | MO | Saint Louis | Trilogy | Lung and other extracranial sites
St. Luke’s Hospital | MO | Chesterfield | Trilogy | NS
University of Missouri/Ellis Fischel | MO | Columbia | Trilogy TX | NS
Baptist Medical Center | MS | Jackson | CyberKnife | Liver, Lung, Pancreas
Mississippi Baptist Medical Center | MS | Jackson | CyberKnife | Liver, Lung, Pancreas
Benefis Healthcare System | MT | Great Falls | CyberKnife | Lung, Pancreas, Prostate
Kalispell Regional Medical Center | MT | Kalispell | Trilogy | NS
Carloinas Medical Center | NC | Charlotte | Novalis TX | NS
Columbus Reg Healthcare System | NC | Whiteville | NR | NS
Duke University Hospital | NC | Durham | Novalis TX | Liver
East Carloina University CyberKnife Center | NC | Greenville | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
Grace Hospital | NC | Morganton | Novalis | NS
Mission Hospitals | NC | Asheville | CyberKnife | Kidney, Liver, Lung, Pancreas
North Carloina Baptist Hospital (Wake Forest University Baptist Medical Center) | NC | Winston-Salem | NR | Lung
University of North Carloina Hospitals | NC | Chapel Hill | CyberKnife | Adrenals, Kidney, Liver, Lung, Pancreas, Prostate
Alegent Health Bergan Mercy M Center | NE | Omaha | Tomotherapy | Breast, Lung, Prostate
Alegent Health Lakeside Hospital | NE | Omaha | Tomotherapy | Breast, Lung, Prostate
Columbus Community Hospital | NE | Columbus | NR | NS
Nebraska Medical Center | NE | Omaha | Novalis | Liver, Lung, Prostate
St. Elizabeth CyberKnife Center | NE | Lincoln | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
Dartmouth-Hitchcock Medical Center | NH | Lebanon | Trilogy | Lung
Elliot Hospital | NH | Manchester | Novalis | Prostate
Huggins Hospital | NH | Wolfeboro | NR | NS
Wentworth-Douglas Medical Center | NH | Dover | Novalis TX, Trilogy TX | NS
Capital Health System at Mercer | NJ | Trenton | CyberKnife | Liver, Lung, Pancreas
CentraState Healthcare System | NJ | Freehold | NR | Liver, Lung
Christ Hospital | NJ | Jersey City | NR | NS
Community Medical Center | NJ | Toms River | Tomotherapy | NS
Cooper CyberKnife Center | NJ | Mount Laurel | CyberKnife | Liver, Lung, Pancreas, Prostate
Cooper Health System | NJ | Camden | CyberKnife | Bone (primary/mets), Liver, Lung, Pancreas, Prostate
Monmouth Medical Center | NJ | Long Branch | Tomotherapy | Lung, Prostate
Morristown Memorial Hospital | NJ | Morristown | CyberKnife | Liver/Lung/Spine (primary/mets), Pancreas, and Prostate
Newark Beth Israel Medical Center | NJ | Newark | Tomotherapy | NS
Overlook Hospital | NJ | Summit | CyberKnife | Liver, Lung, Pancreas, Prostate
Riverview Medical Center | NJ | Red Bank | CyberKnife | Liver, Lung, Pancreas, Pelvis, Prostate
Robert Wood Johnson Univ Hosp | NJ | Hamilton | NR | NS
Robert Wood Johnson Univ Hospital | NJ | New Brunswick | NR | NS
Saint Barnabas Medical Center | NJ | Livingston | Tomotherapy, CyberKnife | Prostate and other extracranial sites
Somerset Medical Center | NJ | Somerset | Novalis TX | NS
University of Medicine -University Hospital | NJ | Newark | Tomotherapy | NS
Valley Hospital | NJ | Ridgewood | Tomotherapy | NS
Presbyterian Hospital | NM | Albuquerque | NR | Lung
Banner Churchill Community Hospital | NV | Fallon | Tomotherapy | NS
CyberKnife of Reno | NV | Reno | CyberKnife | Liver, Lung, Musculoskeletal, Pancreas, Prostate
Renown Regional Medical Center | NV | Reno | Tomotherapy | Bone, Breast, Colon, Gynecolog., Lymph Nodes, Rectum, Pancreas, Stomach
Columbia University | NY | New York | Trilogy TX | NS
CyberKnife Center of New York | NY | Johnson City | CyberKnife | Liver, Lung, Pancreas, Prostate
Highland Hospital of Rochester | NY | Rochester | Tomotherapy, Trilogy, Novalis | Liver and other extracranial sites
Long Island Jewish Medical Center | NY | New Rochelle | NR | NS
Memorial Sloan-Kettering Cancer Center | NY | New York | Trilogy | Bone Mets, Lung, Pelvis, Prostate, Skin
Mount Sinai Hospital | NY | New York | Novalis | Liver, Lung
New York-Presbyterian Hospital | NY | New York | CyberKnife | NS
North Shore University Hospital | NY | Manhasset | Novalis | Liver, Lung, Prostate
Northern Westchester Hospital | NY | Mount Kisco | Trilogy | NS
Roswell Park Cancer Institute | NY | Buffalo | Trilogy | Breast, Liver, Lung, Pancreas, Prostate
St. Peter’s Hospital | NY | Albany | Novalis | Liver, Lung
Stony Brook University Hospital | NY | Stony Brook | NR | NS
Strong Memorial Hospital | NY | Rochester | Novalis, Trilogy | NS
United Health Services Hosp | NY | Binghamton | CyberKnife | Liver, Lung, Pancreas, Prostate
Westchester County Medical Center | NY | Valhalla | Novalis | NS
Winthrop University Hospital | NY | Mineola | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
Cleveland Clinic Foundation | OH | Cleveland | Novalis | Kidney, Liver, Lung
Doctors Hospital | OH | Columbus | Trilogy | Lung
Flower Hospital | OH | Sylvania | Tomotherapy, Trilogy | NS
Grady Memorial Hospital | OH | Delaware | Trilogy | Lung
Grant Medical Center | OH | Columbus | Trilogy | Lung
James Cancer Hospital | OH | Columbus | NR | NS
Jewish Hospital | OH | Cincinnati | Trilogy | NS
Mercy Medical Center | OH | Canton | Trilogy | NS
Precision Radiotherapy | OH | West Chester | Novalis, Tomotherapy | Breast, Gynecol., Liver, Lung, Pancreas, Prostate, Rectum
Riverside Methodist Hospital | OH | Columbus | Trilogy | Lung
Southern Ohio Medical Center | OH | Portsmouth | Synergy | NS
Southwest General Health Center | OH | Middleburg Heights | CyberKnife, Tomotherapy | Breast, Gynecologic, Kidney, Liver, Lung, Pancreas, Prostate
Summa Health System | OH | Akron | Novalis | NS
Univ Hosp Geauga Regional Hospital | OH | Chardon | CyberKnife, Novalis | Liver, Lung, Pancreas, Prostate
University Hospital | OH | Cincinnati | Lexar | NS
University Hospitals Case Medical Center | OH | Cleveland | CyberKnife, Novalis | Breast, Gynecological, Kidney, Liver, Lung, Pancreas, Prostate
Baptist Medical Center | OK | Oklahoma City | Novalis TX | NS
Deaconess Hospital | OK | Oklahoma City | Tomotherapy | Prostate
Hillcrest Medical Center | OK | Tulsa | CyberKnife | NS
Mercy Health Center | OK | Oklahoma City | CyberKnife | NS
Oklahoma CyberKnife | OK | Tulsa | CyberKnife | Liver, Lung, Pancreas, Prostate
OU Medical Center | OK | Oklahoma City | Trilogy | NS
Saint Anthony Hospital | OK | Oklahoma City | CyberKnife | NS
St. John Medical Center | OK | Tulsa | CyberKnife | Liver, Lung, Pancreas, Prostate
Legacy Emanuel Hospital and Health center | OR | Portland | Novalis | Breast, Liver, Lung, Prostate
OHSU Hospital | OR | Portland | Trilogy, Novalis TX | NS
Providence Portland Medical Center | OR | Portland | CyberKnife | Lung
Abington Memorial Hospital | PA | Abington | NR | NS
Allegheny General Hospital | PA | Pittsburgh | Xknife | Lung
Easton Hospital | PA | Easton | Tomotherapy, Trilogy | NS
Fox Chase Cancer Center | PA | Philadelphia | Trilogy, CyberKnife | Lung mets (Trilogy), NS (CyberKnife)
Frankford Hospital | PA | Philadelphia | Trilogy | Prostate
Geisinger Medical Center | PA | Danville | Trilogy | Lung
Hamot Medical Center | PA | Erie | Trilogy | NS
Hospital of the Univ of PA | PA | Philadelphia | Trilogy, Oncor, Synergy | NS
Lankenau Hospital | PA | Wynnewood | NR | NS
Meadville Medical Center | PA | Meadville | Trilogy | NS
Penn State Milton S. Hershey Medical Center | PA | Hershey | Trilogy | NS
Pennsylvania Hospital | PA | Philadelphia | Trilogy, Oncor | NS
Philadelphia CyberKnife Center | PA | Havertown | CyberKnife | Liver, Lung, Musculoskeletal, Pancreas, Pelvis, Prostate
Pocono Medical Center | PA | East Stroudsburg | NR | NS
Reading Hospital and Medical Center | PA | West Reading | Trilogy | Kidney, Liver, Lung, Pancreas
St. Luke’s Hospital - Bethlehem Campus | PA | Bethlehem | Trilogy | Lung
St. Luke’s Miner’s Memorial Hospital | PA | Coaldale | Trilogy | Lung
Temple University Hospital | PA | Philadelphia | Synergy | NS
Thomas Jefferson University Hospital | PA | Philadelphia | Novalis | NS
UPMC Bedford Memorial | PA | Everett | Trilogy | NS
UPMC Mercy | PA | Pittsburgh | Trilogy, Cyberknife | NS
UPMC Presbyterian | PA | Pittsburgh | Trilogy | NS
UPMC Shadyside Hospital | PA | Pittsburgh | Trilogy, Cyberknife | Abdomen, Lung, Pelvis
Western Pennsylvania Hospital | PA | Pittsburgh | XKnife | Lung
HIMA San Pablo | PR | Caguas | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
Rhode Island Hospital | RI | Providence | Trilogy, CyberKnife | Breast, Kidney, Liver, Lung, Pancreas, Pelvis, Prostate, Skin
Cancer Centers of the Carloinas and Greenville Hospital System | SC | Greenville | Novalis | Liver, Lung, Prostate
MUSC Medical Center | SC | Charleston | Tomotherapy | Abdomen, Prostate
Roper Hospital | SC | Charleston | CyberKnife | Liver, Lung, Pancreas, Prostate
Sanford Univ of SD Medical Center | SD | Sioux Falls | Novalis | NS
Centennial Medical Center | TN | Nashville | CyberKnife | Liver, Lung, Pancreas, Prostate
University of Tennessee Medical Center | TN | Knoxville | CyberKnife | Liver, Lung, Pancreas, Prostate
Vanderbilt University | TN | Nashville | Novalis TX | NS
Wellmont Bristol Regional Med Center | TN | Bristol | CyberKnife | NS
Baylor Medical Center at Garland | TX | Garland | CyberKnife | NS
Baylor/Sammons Cancer Center | TX | Dallas | Novalis TX | NS
Baylor University Medical Center | TX | Dallas | CyberKnife | NS
Brain and Spine Center/Brackenridge Hospital | TX | Austin | CyberKnife | Liver, Lung, Pancreas, Prostate
East Texas Medical Center Tyler | TX | Tyler | CyberKnife | Lung, Pancreas, Prostate
Harris Methodist Hospital | TX | Fort Worth | Novalis TX | NS
Memorial Herman Hospital SW | TX | Houston | Trilogy TX | NS
Methodist Hospital | TX | San Antonio | CyberKnife, Novalis, Tomotherapy | Liver, Lung, Prostate
North Cypress Medical Center | TX | Cypress | NR | Kidney, Liver/Lung Mets, Lung, Pancreas, Pelvis, Prostate
Richardson Regional Medical Center | TX | Richardson | Novalis | Liver, Lung, Prostate
South Texas Oncology and Hematology at the START Center | TX | San Antonio | CyberKnife, Tomotherapy | NS
Spring Branch Medical Center | TX | Houston | NR | Adrenals, Liver, Lung, Pancreas, Pelvis, Prostate
St. Luke’s Episcopal Health System Corp. | TX | Houston | CyberKnife | Kidney, Liver, Lung, Pancreas, Prostate
Tyler Cancer Center | TX | Tyler | Novalis TX | NS
Texas Health Harris Methodist Fort Worth | TX | Fort Worth | CyberKnife | NS
Texas Health Presbyterian Hosp | TX | Dallas | CyberKnife | NS
The Methodist Hospital | TX | Houston | NR | Liver, Lung
Univ of TX (CTRC) | TX | San Antonio | Novalis TX | NS
Univ of TX M. D. Anderson Cancer Center | TX | Houston | NR | Lung
Univ of TX Medical Branch | TX | Galveston | Novalis | Abdomen, Liver, Lung
Univ of TX Southwestern Medical Center | TX | Dallas | CyberKnife | Prostate and other extracranial sites
Walls Regional Hospital | TX | Cleburne | CyberKnife | Liver, Lung, Pancreas, Prostate
Primary Children’s Medical Center | UT | Salt Lake City | Trilogy | NS
Salt Lake CyberKnife | UT | Salt Lake City | CyberKnife | Liver, Lung, Musculoskeletal, Pancreas, Prostate
University of Utah | UT | Salt Lake City | Novalis | NS
Carilion Health | VA | Roanoke | CyberKnife | Kidney, Lung, Pancreas, Prostate
Carilion New river Valley Medical Center | VA | Christiansburg | CyberKnife | NS
Centra Health | VA | Lynchburg | Trilogy | NS
CJW Medical Center | VA | Richmond | Trilogy | NS
Inova Fairfax Hospital | VA | Falls Church | NR | Skeletal
Riverside Regional Medical Center | VA | Newport News | Synergy | NS
Sentara Advanced Radiosurgery Center | VA | Norfolk | CyberKnife | Liver, Lung, Pancreas
University of Virginia Medical Center | VA | Charlottesville | Tomotherapy | Liver, Lung
VCU Health System | VA | Richmond | Tomotherapy | NS
Virginia Hospital Center | VA | Arlington | CyberKnife | Lung, Prostate
Harborview Medical Center | WA | Seattle | NR | NS
Multicare Health System | WA | Tacoma | Trilogy | NS
Southwest Washington Medical Center | WA | Vancouver | CyberKnife | Kidney, Liver, Lung, Pancreas, Pelvis
St. Joseph Hospital | WA | Bellingham | Tomotherapy | Gastrointestinal, Gynecologic, Prostate
Swedish Health Services | WA | Seattle | CyberKnife, Synergy | NS
Swedish Medical Center | WA | Seattle | CyberKnife, Synergy | Prostate
University of Washington Med Center | WA | Seattle | Tomotherapy | NS
Virginia Mason Medical Center | WA | Seattle | NR | Prostate
Appleton Medical Center | WI | Appleton | CyberKnife, Tomotherapy, Trilogy | NS
Aurora Medical Center | WI | Kenosha | CyberKnife | Lung, Pancreas
Aurora Memorial Hospital of Burlington | WI | Burlington | CyberKnife | Lung, Pancreas
Aurora St. Luke’s Medical Center | WI | Milwaukee | CyberKnife | Lung, Pancreas
Columbia St. Mary’s - Columbia Campus | WI | Milwaukee | Trilogy | Breast, Kidney, Liver, Lung, Pancreas, Pelvis, Prostate, Skin
Saint Joseph’s Hospital | WI | Marshfield | Trilogy | NS
St. Vincent Hospital | WI | Green Bay | Trilogy | NS
Theda Clark Medical Center | WI | Neenah | CyberKnife, Tomotherapy | NS
University of Wisconsin Hosp | WI | Madison | Tomotherapy | NS
Waukesha Memorial Hospital | WI | Waukesha | CyberKnife | Liver, Lung, Pancreas, Prostate
Wheaton Franciscan Cancer Care – St. Joseph | WI | Glendale | Novalis | NS
St. Mary’s CyberKnife Center | WV | Huntington | CyberKnife | Kidney, Liver, Lung, Pancreas, Pelvis

NR: Not reported

NS: Not specified