# Literature Search Methods

A variety of approaches were used to identify relevant information for this report, including searches of peer-reviewed literature, gray literature, and federal regulations.

Part I. This portion of the search report includes searches of bibliographic resources. ECRI Institute’s search strategies employ combinations of free text keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. The strategies presented below are in OVID syntax; the searches were simultaneously conducted across EMBASE, MEDLINE, and CINAHL. Parallel strategies based on MeSH headings and keywords were used to search the databases comprising the Cochrane Library.

## Electronic Database Searches

The following databases have been searched for relevant information:

Name | Date Limits | Platform/Provider
The Cochrane Central Register of Controlled Trials (CENTRAL) | Through 2010, Issue 3 | www.thecochranelibrary.com
The Cochrane Database of Methodology Reviews (Methodology Reviews) | Through 2010, Issue 3 | www.thecochranelibrary.com
The Cochrane Database of Systematic Reviews (Cochrane Reviews) | Through 2010, Issue 3 | www.thecochranelibrary.com
Database of Abstracts of Reviews of Effects (DARE) | Through 2010, Issue 3 | www.thecochranelibrary.com
EMBASE (Excerpta Medica) | 1980 through December 29, 2010 | OVID
Health Technology Assessment Database (HTA) | Through 2010, Issue 3 | www.thecochranelibrary.com
MEDLINE | 1990 through December 29, 2010 | OVID
PreMEDLINE | Searched March 18, 2010 | National Library of Medicine
U.K. National Health Service Economic Evaluation Database (NHS EED) | Through 2010, Issue 3 | www.thecochranelibrary.com
U.S. National Guideline Clearinghouse™ (NGC) | Searched November 7, 2008 | www.ngc.gov

## Hand Searches of Journal and Nonjournal Literature

Journals and supplements maintained in ECRI Institute’s collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.)

The search strategies employed combinations of free text keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. The strategy below is presented in OVID syntax; the search was simultaneously conducted across EMBASE and MEDLINE. A parallel strategy was used to search the databases comprising the Cochrane Library.

## Medical Subject Headings (MeSH), EMTREE, PsycINFO and Keywords

### Conventions

#### OVID

$ = truncation character (wildcard)

exp = “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary’s hierarchy)

.de. = limit controlled vocabulary heading

.fs. = floating subheading

.hw. = limit to heading word

.md. = type of methodology (PsycINFO)

.mp. = combined search fields (default if no fields are specified)

.pt. = publication type

.ti. = limit to title

.tw. = limit to title and abstract fields

#### PubMed

[mh] = MeSH heading

[majr] = MeSH heading designated as major topic

[pt] = publication type

[sb] = subset of PubMed database (PreMEDLINE, Systematic, OldMEDLINE)

[sh] = MeSH subheading (qualifiers used in conjunction with MeSH headings)

[tiab] = keyword in title or abstract

[tw] = text word

## Topic-Specific Search Terms

Many controlled vocabulary terms and keywords were considered for inclusion in the search strategies. The following table contains an alphabetical listing of terms and keywords grouped by broad concepts. These are the terms and keywords that were actually included in the final search strategies.

Concept | Controlled Vocabulary | Keywords
Cancer | exp neoplasm/ exp neoplasms/ | acoustic neuroma$ antibody therap$ biops$ brain$ cranial nerve Da Vinci epileps$ farnesyl transferase inhibitor$ glioma$ gliomastosis hemangiocytoma$ hemangiopericytoma$ herpceptin laparoscop$ mdl medulloblastoma$ meningioma$ neurocytoma$ oligodendroglioma$ pinealoma$ pituitary plesiomorphic robot-assisted tumo?r$ xanthoastrocytoma$
Device | | American Radiosurgery Brainlab Cyber knife Cyberknife Cyber-knife Elekta Elekta Axesse ExacTrac Gamma ART 6000 Gamma knife Linac Novalis Perfexion Rotating Gamma System Vertex360 Synchrony Synergy Synergy Trilogy XKnife
Radiosurgery | Radiosurgery/ Robotics/ Stereotaxic surgery/ Surgery, computer-assisted/is | hypo fractionated hypofractionated radiosurg* radiosurgery radiotherapy real-time tumor tracking robotic single-dose single-fraction stereotactic stereotaxis

### English Embase/Medline

English language, human, remove overlap

Set Number | Concept | Search Statement
1 | Device | (Gamma knife or Cyber knife or Cyberknife or Cyber-knife or linac or Novalis or Trilogy or XKnife or Synchrony or Synergy or Elekta or Elekta Axesse or Perfexion or Gamma ART 6000 or American Radiosurgery or Rotating Gamma System Vertex360 or Synergy or ExacTrac or BrainLAB).mp.
2 | Radiosurgery | Radiosurgery/ or Robotics/ or Surgery, computer-assisted/is or Stereotaxic surgery/ or real-time tumor tracking.mp. or (robotic and (radiotherapy or radiosurgery)).mp. or (radiosurg* and (stereotactic or stereotaxis or hypo fractionated or hypofractionated or single-fraction or single-dose)).mp.
3 | Combine sets | 1 or 2
4 | Cancer | exp neoplasms/ or exp neoplasm/ or (neoplasm$ or cancer$ or carcinoma$ or adenoma$ or sarcoma$ or tumo?r$).mp.
5 | Combine sets | 3 and 4
6 | Cancer of the brain | (Tumo?r$ adj2 (brain$ or pituitary or cranial nerve)).ti.
7 | | (Glioma$ or gliomastosis or hemangiocytoma$ or hemangiopericytoma$ or medulloblastoma$ or mdl or meningioma$ or neurocytoma$ or oligodendroglioma$ or pinealoma$ or plesiomorphic xanthoastrocytoma$ or acoustic neuroma$ or epileps$ or herpceptin or robot-assisted or laparoscop$ or antibody therap$ ir farnesyl transferase inhibitor$ or Da Vinci or biops$).ti.
8 | Combine sets | 6 or 7
9 | | 5 not 8
10 | Remove overlap | Remove duplicates from 9

Part 2. The following databases have been searched for relevant information for Guiding Questions 1 and 2.

Name | Date Limits | Platform/Provider
ClinicalTrials.gov | Searched 11/13/08, 09/22/2009, and 03/23/10 | www.clinicaltrials.gov
ECRI Institute cross-search | Searched 5/28/2009 | www.ecri.org
Lexis-Nexis Major Newspapers | Searched 8/20/08 | www.lexis.com
U.S. National Guideline Clearinghouse™ (NGC) | Searched 11/7/08 | www.ngc.gov

The following Web sites have been mined for information.

Name | Date Limits | URL
Centers for Medicare and Medicaid Services (CMS) | 4/30/2009 | www.cms.gov