# Acknowledgments

The ECRI Institute Evidence-based Practice Center thanks Eileen Erinoff, MSLIS, and Helen Dunn for providing literature retrieval and documentation management support and Lydia Dharia and Katherine Donahue for their assistance with the preparation of the Technical Brief. We also acknowledge the contributions of Curtis Miyamoto, M.D., Chairperson, Department of Radiation. Oncology and Professor, Department of Radiation Oncology, Temple University School of Medicine in reviewing drafts of this report.