# Acknowledgments

We are indebted to the tireless, timely, and insightful assistance of colleagues who made this technical brief possible:

Ms. Allison Glasser provided research assistance on this report, including assisting with gray literature research on the Internet, carefully constructing many tables and efficiently coordinating key informant discussions.

Ms. Toye Spencer oversaw the completion and formatting of the summary tables, and other critical elements of the report as a whole.