# Acronyms/Abbreviations

AHRQ: Agency for Healthcare Research and Quality
AR: Amnioreduction
ASD: Atrial septal defect
BPS: Bronchopulmonary sequestration
CCAM: Congenital cystic adenomatoid malformation
CDC: Centers for Disease Control and Prevention
CDH: Congenital diaphragmatic hernia
CM: Chiari malformation
CPAM: Congenital Pulmonary Airway Malformation
CSF: Cerebrospinal fluid
CVPS: Cardiovascular Profile Score
DNA: Deoxyribonucleic acid
ECMO: Extracorporeal membrane oxygenation
EPC: Evidence-based Practice Center
FETO: Fetoscopic tracheal occlusion
FHI: Fetal hemodynamic instability
G: Group
HLHS: Hypoplastic left heart syndrome
IUFD: Intrauterine fetal death/In utero fetal demise
IVH: Intraventricular hemorrhage
LHR: Lung-to-head ratio
MeSH: Medical Subject Headings
MMC: Myelomeningocele
mo/mos: Months
MOMS: Management of Myelomeningocele Study
MRI: Magnetic resonance imaging
NA: Not applicable
NIH: National Institutes of Health
PROM: Premature rupture of membranes
PUV: Posterior urethral valves
RCT: Randomized controlled trial
RDS: Respiratory Distress Syndrome
RFA: Radiofrequency ablation
SD: Standard deviation
SFLP: Selective fetoscopic laser photocoagulation
SLPCV: Selective laser photocoagulation of communicating vessels
TTTS: Twin-twin transfusion syndrome
U.S.: United States
UK: United Kingdom
US: Ultrasound