# Results

## State of the Science

We present an overview of the state of the science for each of the seven conditions that are the focus of this report. As possible, we have attempted to either combine related publications in the citations or call the reader’s attention to overlap. Total numbers of participants in text and tables overestimates the number of pregnancies because not all duplicate inclusions, especially those from registries and databases, can be deciphered from the information in the publications. Table 2 presents summary information for the studies included in this brief. Five studies were reported in the 1980s, 37 in the 1990s, and 121 since 2000.

Table 2 Overview of maternal-fetal surgical procedures literature

Study Characteristic | Cardiac malformations | Congenital diaphragmatic hernia | Myelomeningocele | Obstructive uropathy | Sacrococcygeal teratoma | Thoracic lesions (CCAM and BPS) | Twin-twin transfusion syndrome | Total Literature
Study Populations | (n=9) | (n=21) | (n=11) | (n=25) | (n=5) | (n=11) | (n=84) | (n=166)
U.S. | 6 | 12 | 11 | 14 | 4 | 6 | 21 | 74
European | 2 | 9 | 0 | 4 | 1 | 3 | 49 | 68
Asian | 0 | 0 | 0 | 2 | 0 | 1 | 5 | 8
Other | 1 | 0 | 0 | 5 | 0 | 1 | 9 | 16
Study Type
Case series | 9 | 12 | 4 | 14 | 1 | 3 | 73 | 116
Retrospective cohort | 0 | 5 | 6 | 8 | 4 | 7 | 6 | 36
Prospective cohort | 0 | 3 | 1 | 3 | 0 | 1 | 3 | 11
Randomized clinical trial | 0 | 1 | 0 | 0 | 0 | 0 | 2 | 3
Approaches Assessed *
Hysterotomy | 1 | 8 | 9 | 3 | 3 | 3 | 4 | 31
Laparoscopic | 0 | 12 | 2 | 0 | 1 | 2 | 7 | 24
Percutaneous | 9 | 7 | 0 | 24 | 5 | 9 | 49^†^ | 103
Last Infant Outcome Assessment
Birth | 6 | 3 | 1 | 9 | 2 | 4 | 22 | 47
≤ 6 months | 1 | 9 | 2 | 2 | 0 | 2 | 19 | 35
> 6 to ≤ 12 months | 0 | 1 | 4 | 1 | 0 | 1 | 1 | 8
> 12 months | 2 | 8 | 4 | 11 | 3 | 4 | 19 | 51
Unknown | 0 | 0 | 0 | 2 | 0 | 0 | 23 | 25
Total Pregnancies: ^ | 90 | 503 | 262 | 450 | 130 | 414 | 2532 | 4381

BPS=bronchopulmonary sequestration; CCAM=Congenital Cystic Adenomatoid Malformation

* Total is greater than number of studies, some publications report more than one approach.

^ Minus duplication reported by authors.

† Surgical approach is not clearly reported, therefore totals to less than 84 studies.

## State of the Science: Cardiac Malformations

Background. In utero interventions are being performed for cardiac conditions including: Pulmonary atresia with intact ventricular septum (very narrow pulmonary valve without a connection between the right and left ventricles), critical aortic stenosis with impending hypoplastic left heart syndrome (HLHS) (very small, nonfunctional left ventricle, hypothesized by some investigators to be from underuse secondary to a severely narrow aortic valve), and hypoplastic left heart syndrome with intact atrial septum (no connection between the left and right atrium). All of these conditions, if untreated either in utero or soon after birth, are lethal.

Critical pulmonary stenosis or atresia with intact ventricular septum. These anomalies portend a poor prognosis. A prospective prevalence study in Canada showed that overall survival was 77 percent at one month and 58 percent at 15 years.1 Fetal intervention to relieve the stenosis and allow for ventricular growth could theoretically increase the number of patients who ultimately end up with a biventricular repair. There is some debate as to whether this is an adequate measure of success since the right ventricle in a two-ventricle repair still has abnormal diastolic dysfunction and may not lead to increased exercise capacity.2 However, these studies were performed in patients who had not undergone in utero repair. It is possible that if the stenosis is relieved early enough in gestation that there may be adequate time before delivery for growth of the right ventricle. In fetuses with impending hydrops, in utero valvuloplasty could reverse the condition and prevent hydrops and death.

Included publications. We identified two published reports3–4 of in utero fetal pulmonary balloon valvuloplasty in fetuses with pulmonary atresia of intact ventricular septum meeting our inclusion criteria (Table 3). Tulzer’s case series3 describes two patients who underwent in utero pulmonary balloon valvuloplasty at a specialty center in Europe. One fetus was diagnosed at 28 weeks and the other at 30 weeks gestation; both had imminent hydrops, which was not defined in the paper. Both fetuses showed successful valve perforations and immediate improvement in right ventricular function. Both fetuses sustained spontaneously resolving pericardial effusions.

Table 3 Summary of case series of maternal-fetal surgical procedures for cardiac malformations

Author Year | With fetal procedure, N^*^ | Fetal inclusion criteria provided? | Maternal inclusion criteria provided? | Comparison group | Outcomes beyond neonatal hospital stay?
Pulmonary atresia and intact ventricular septum
Mizrahi-Arnaud et al.4 2007 | 8 | No | No | None | No
Tulzer et al.3 2002 | 2 | Yes | No | None | Yes
Aortic stenosis with developing hypoplastic left heart syndrome (HLHS)
McElhinney et al.5–6 2009 | 70 | Yes | No | Yes | Yes
Mizrahi-Arnaud et al.4 2007 | 50 | No | No | No | Yes
Wilkins-Haug et al.7 2006 | 22 | Yes | No | No | No
Marshall et al.8 2005 | 26 | No | No | No | Yes
Tworetzky et al.9 2004 | 14 | No | No | No | Yes (30 mos)
Kohl et al.10 2000^*^ | 12 | No | No | No | Yes
Maxwell et al.11 1991 | 2 | No | No | No | Yes
Intact atrial septum studies
Marshall et al.2004^12^ 2008^13^ | 19 | Yes | No | No | No
Mizrahi-Arnaud et al.4 2007 | 20 | Yes | No | No | No

* These totals represent an unknown number of duplicated cases; estimated total of unique cases is 93.

No maternal selection criteria were noted. General maternal anesthesia was used in one case, and local maternal anesthesia was used in the second case. There was no additional fetal anesthesia used in the case with general maternal anesthesia. In the case with local maternal anesthesia, the fetus was given fentanyl, pancuronium, and atropine through the intrahepatic vein.

Both fetuses developed restenosis of the valve which prompted delivery, one at 38 weeks + 2 days and the other at 35 weeks + 3 days. Both required postnatal balloon pulmonary valvuloplasty and systemic-to-pulmonary shunt. They were both reported to have biventricular circulation at 18 and 12 months of life.

Mizrahi-Arnaud’s publication4,8 regarding experience with fetal hemodynamic instability in 83 fetuses undergoing 3 different fetal cardiac surgeries included 8 patients with pulmonary atresia with evolving hypoplastic right heart syndrome (HRHS). Six of the eight fetuses experienced major fetal hemodynamic instability (defined as fetal heart rate ≤110 min^−1^ for ≥30 min with ventricular dysfunction of the dominant ventricle requiring resuscitation). There was no information provided on fetal inclusion criteria or survival of procedure, to birth, or beyond.

Critical aortic stenosis. Severe aortic stenosis, a very narrow aortic valve that develops early during gestation, may result in HLHS. In utero aortic balloon valvuloplasty has been suggested as a way to relieve aortic stenosis, thus preserving left ventricular growth and halting progression to HLHS.

The first described attempt at in utero balloon aortic valvuloplasty was reported by Maxwell in London in 1991. The same group reported the first survivor in a case report in 1995.^14^ Since then, there have been scattered attempts at this procedure around the world, but the most abundant work has been performed by the fetal surgery team at Children’s Hospital Boston, Massachusetts.

Included publications. For this technical brief, we identified eight publications.4–11 The fetal surgery team at Children’s Hospital Boston has published several papers about its experience with a series of patients undergoing balloon dilation for severe aortic stenosis, some with additional participants and others with followup of the same participants. There is one publication from the United Kingdom11 and one publication that pools data from six international centers,10 including the aforementioned site in the United Kingdom. Two centers in Germany, two in Brazil, and an additional one in the United States (Pennsylvania) perform the procedures.

All publications are prospective case series that took place between 1989 and 2010. An estimated total of 90 fetuses underwent in utero balloon aortic valvuloplasty (the literature includes reports of 154 with some level of duplication). Seventy patients are from Boston. Technical successes have improved over time and appear to be related to center and team experience. In 2000, Kohl10 reported on 12 cases in 6 different centers in Europe, Brazil, and the United States (the first 2 reported cases were also published separately by Maxwell in 1991). Technical success was achieved in 7 of 12 (58 percent), but 4 of 7 (57 percent) of those fetuses died within 24 hours of the procedure. By 2009, McElhinney5 was reporting technical success in 52 of 70 (74 percent) cases with 5 of 50 (10 percent) of the technical successes resulting in fetal loss or stillbirth. Of the technical successes, 15 of 45 with live birth (33 percent) were born with a biventricular circulation, and 28 of 4,514 (62 percent) were born with HLHS. Of the 18 (26 percent) who had technical failures, 14 survived to birth, and all were born with HLHS. When the numbers of fetal deaths are included (excluding terminations for any reason), the rate of loss was 9 of 68 (13 percent) in those who underwent a procedure, whether successful or not, and 3 of 14 participants who declined procedures had neonatal deaths (21 percent). It is difficult to determine whether the procedure changes long-term outcomes, since it appears to increase risk of fetal loss but potentially prevent neonatal deaths

Table 4 Primary outcomes of maternal-fetal surgical procedures for cardiac malformations

Author, Year, Country | Key outcomes
Pulmonary atresia with intact ventricular septum
Mizrahi-Arnaud et al.4 2007^*^ U.S. | - Focuses on fetal hemodynamic instability (FHI), defined as fetal heart rate ≤110 min^−1^ for ≥30 min with ventricular dysfunction of dominant ventricle. Major FHI if required resuscitation. Minor FHI if no intervention required; - 6 of 8 (75%) had major FHI. More likely in younger fetuses (p=0.03) and those with hemopericardium (p=0.07); - No fetal outcomes regarding procedure success, survival to birth or neonatal survival are available
Tulzer et al.3 2002 Austria | - 2 fetuses with imminent hydrops (undefined) had valvuloplasty; - 35 weeks and 38 weeks at birth; follow up at 12 and 18 months
Aortic stenosis with developing HLHS
McElhinney et al.5–6 2009 | - 59 of 70 (84%) with attempted procedures survived to viability at birth; - 15 of 50 (30%) with successful procedures had biventricular circulation at birth; - Of those without biventricular circulation at birth (n=30), 2 died without intervention, 1 had heart transplant and died, 3 died after neonatal procedures; 2 achieved biventricular circulation via surgeries in childhood.; - Prenatal aortic valvuloplasty does not reverse abnormally low cerebrovascular impendence observed in studies of cerebral blood flow in fetuses with HLHS.
Mizrahi-Arnaud et al.4 2007^*^ U.S. | - No differentiation in outcomes between pulmonary valvuloplasty and aortic valvuloplasty so many outcomes are overall for both; - 45% had major FHI; - More likely in younger fetuses (p=0.03) and those with hemopericardium (p=0.07); - No fetal outcomes regarding procedure success, survival to birth or neonatal survival available
Wilkins-Haug et al.7 2006^*^ U.S. | - Only assessed factors affecting technical success; - Descriptive series 22 fetuses
Marshall et al.8 2005^*^ U.S. | - 14 of 26 (54%) performed percutaneously; - 22 cases laparotomies; - 20 of 26 technically successful. Neither gestational age nor annulus size associated with technical success
Tworetzky et al.9 2004^*^ U.S. | - Technical success in 14 of 20; - 2 of 14 in utero demise; - 3 of 14 (21%) born with 2 functioning ventricles, 2 required procedures in first week of life; - 6 of 14 had HLHS; of the technical failures, 1 of 6 terminated, 3 of 6 HLHS, 2 of 6 fetal demise
Kohl et al.10 2000 Europe, Brazil, U.S. | - 12 fetuses in 6 different centers in Europe, Brazil, U.S.; - 5 technical failures; 1 of 5 (20%) of these survived long-term; - 1 of 7 (14%) who survived prenatal intervention survived long-term; - Four fetuses died within 24 hours after procedure from bleeding, bradycardia and valvotomy following emergency delivery; two cesarean sections and one chorioamnionitis
Maxwell et al.11 1991 U.K. | - 2 fetuses with critical aortic stenosis. One fetal demise within 24 hours of technically unsuccessful procedure; - One neonatal death from heart failure after one technically unsuccessful attempt and one successful attempt
Hypoplastic left heart with intact atrial septum
Marshall et al.13 2008^*^ U.S. | - 19 of 21 successful atrial septoplasty (excluded hydropic fetuses); - Fetal bradycardia, pericardial effusion, or pleural effusion in 8 of 21 (38%); - 12 of 19 required urgent intervention at birth; - 7 of 19 underwent routine stage I postnatal surgery; - Overall survival including two fetal demises 11 of 21 (58%)
Mizrahi-Arnaud et al.4 2007^*^ U.S. | - Focuses on fetal hemodynamic instability defined as fetal heart rate ≤110 min^−1^ for ≥30 min with ventricular dysfunction of dominant ventricle; - No major (requiring resuscitation) fetal hemodynamic instability from septoplasty; Minor FHI (no intervention required) occurred in 1 patient

FHI = fetal hemodynamic instability; HLHS=hypoplastic left heart syndrome

* Overlapping populations

Three successive papers were published by the same group, each focusing on different aspects related to the procedure: technical characteristics of successful balloon dilation,8 examination of factors affecting technical success, and fetal hemodynamic instability during intervention. In all, they performed at least 50 attempts at in utero aortic valvuloplasty. Because each of these subsequent studies has an independent focus, some during a very narrow time period, it is impossible to tell the overall success rate, survival to birth, and cardiac function and need for surgery postnatally. None of these publications focus on long-term outcomes, so it is difficult to determine whether there is an increase in biventricular function, and even whether any biventricular function is clinically superior to a univentricular circulation. There is also no published data discussing long-term survival and neurologic outcomes of these patients.

It does appear clear that technical success improves over time within a dedicated team and center. The group in Boston improved their success rate from 25 percent to 90 percent8 over a period of several years. All procedures were performed percutaneously except for 12 laparotomies for failed percutaneous attempts (due to fetal positioning and maternal habitus). This is the only information available regarding maternal inclusion criteria, and there is limited information on maternal outcomes.

Hypoplastic left heart syndrome and intact atrial septum. The Centers for Disease Control and Prevention (CDC) estimates that each year about 975 babies in the United States are born with HLHS.15–16 In other words, each year about 2 out of every 10,000 babies born will be born with HLHS. Given the high mortality of infants with HLHS and intact atrial septum, considered to be due to the pulmonary vasculopathy that develops before birth, in utero atrial septostomy has been performed in an attempt to improve postnatal survival. The first report of a balloon atrial septoplasty was in 2004. There is also a single case report using a laser to perform atrial septoplasty.17 In two cases of balloon septoplasty, teams were unable to achieve technical success due to inability to reach the fetal left atrium.17

Included publications. We identified four publications reporting on the creation in utero of an atrial septal defect (ASD). Of these, three met criteria for inclusion.4, 12–13 The fourth paper is the only published report using a laser to perform atrial septoplasty on a fetus but was excluded from evaluation since it was a single case report.18 The first report of in utero creation of an ASD was published in 2004 by a large academic center that specializes in fetal cardiac surgery.12 All publications included were case series from this group and represent one distinct population with additional participants in each subsequent publication for a total of 24 patients between 2001 and 2007.^13^ There are no reports of this procedure being performed outside the United States.

Patients were consecutive fetuses diagnosed via fetal echocardiogram with HLHS and either an intact atrial septum or a ≤ 1mm ASD. Three patients had hydrops fetalis and were excluded from evaluation in the more recent publication. The fetuses were between 23 and 34 weeks gestation at time of intervention. The atrial septum was approached from the right in all but two of the cases.

Technical success was defined by documentation of passage and inflation of the balloon catheter across the atrial septum and echocardiographic flow across a new septal defect.13 There was technical success in at least 19 of 21 cases (90 percent).12–13 At least two of the three hydropic cases were a technical success. The two technical failures were because the introducer could not reach the fetal left atrium due to a combination of introducer length, maternal habitus, and fetal position.13

Fetal complications occurred in 8 of 21 cases (38 percent) and included bradycardia, pericardial effusion, or pleural effusion. Complications occurred in five of nine cases (56 percent) with a larger cannula compared to three of 11 cases (27 percent, p=0.36) with a smaller cannula. Two fetuses, both which developed hemopericardium, died within 24 hours of the procedure.13 At least one was hydropic. Another hydropic fetus died after delivery at 34 weeks due to respiratory compromise. All 19 underwent a stage I procedure, and overall surgical survival was 11 of 19 (58 percent). Of the non-hydropic fetuses, 12 of 19 (63 percent) required an urgent left atrial decompression and surgical survival was 5 of 12 (42 percent) compared to 5 of 7 (86 percent) in patients who underwent a routine stage I procedure.

No maternal selection criteria were provided. The average length of hospitalization was 2.4 ± 1 days.12–13 One woman developed preintervention mirror syndrome (a form of severe preeclampsia) and postoperatively developed an oxygen requirement, which resolved with diuresis, and cellulitis. No maternal deaths or blood transfusion were reported. There is no report of long-term maternal outcomes.

HLHS with intact atrial septum has a poor prognosis, despite the availability of aggressive postnatal surgical options. The attempts to improve the outcomes by creating an adequate atrial septum in utero to allow for a routine stage I palliation have met with technical success. However, the mortality remains high, and there are no randomized controlled trials available to adequately compare the outcomes in patients treated prenatally with those treated postnatally, especially regarding need for definitive postnatal surgical repair. There is no data available on long-term neurologic outcomes.

Summary of fetal cardiac intervention literature. The procedures for severe fetal cardiac anomalies are in developmental stages. As is the history in most areas of new surgical interventions, preliminary work is based in a few highly specialized centers which are laying the groundwork for better understanding the feasibility and subsequent directions for outcomes research in this area. Key informants in our process identified as the most pressing challenge in this area the ability to identify the “right” patient whose care would be compromised by waiting to do a postnatal repair. They stressed the need for more work in developing tools for patient selection in this area. Future research should also include better controlled observational studies and investigate animal and other models to assist in the evaluation of fetal cardiac intervention.

## State of the Science: Congenital Diaphragmatic Hernia

Congenital diaphragmatic hernia (CDH) results from abnormal development of the diaphragm which allows abdominal organs like the bowel, the stomach, and the liver to protrude into the chest cavity. CDH is an important, relatively common congenital malformation, with incidence in the United States of approximately one in every 2,500 births.19–20 Fetuses diagnosed in utero as a result of maternal symptoms have mortality risk approaching 75 percent in some older reviews. One of the paradoxes of diaphragmatic hernia care is a trend toward improved outcome of fetuses not diagnosed before birth. This may reflect the fact that less severe lesions, without the findings of liver in the chest, stomach in the chest, or increased amniotic fluid volume are less likely to be detected by routine ultrasound.

Less invasive fetal procedures have more recently focused on methods to accomplish tracheal occlusion. Occluding the trachea of a fetus results in buildup of lung secretions in the pulmonary tree, gradually distending the lungs as well as triggering complex changes in maturation, including DNA synthesis, epithelial and endothelial proliferation, increased phospholipid metabolism, and surfactant synthesis. The growing lungs push the bowel and abdominal contents out of the chest cavity to an extent and promote improved lung growth.

Included publications. Our search for reports of fetal interventions for congenital diaphragmatic hernia identified 25 publications21–45 with 21 unduplicated populations.

These 21 studies included data from 10 U.S. sites, 9 European, 3 multinational, and 5 from other countries. The Harrison group at the University of California, San Francisco is responsible for the largest number of papers that met criteria for this review, with seven of the publications reflecting their institution and approaches. Of the 21 reports summarized here, 1 is a randomized clinical trial with 3 publications;21,29,38 3 are prospective cohort studies;25,31,45 5 are retrospective cohorts;22,35,37,41,43 and the balance are case series (Table 5).

Table 5 Summary of maternal-fetal surgical procedures for congenital diaphragmatic hernia

Author Year | Tracheal occlusion cases N | Other infants N | Fetal inclusion criteria? | Maternal inclusion criteria? | Comparison group | Outcome beyond neonatal hospital stay?
Randomized clinical trials
Cortes et al.21, 29, 38 2005 | 11 | 13 | Yes | Yes | No fetal procedure | Yes (24 mos)
Total | 11 | 13 | 1 of 1 | 1 of 1 | 1 of 1 | 1 of 1
Prospective cohorts
Cannie et al.45 | 40 | 18 | Yes | No | No fetal procedure | No
Harrison et al.31 1998 | 8 | 13 (open repair) 13 (no procedure) | Yes | Yes | Open repair; no fetal procedure | No (unclear)
Harrison et al.25 1997 | 0 | 4 (open repair) 7 (no procedure) | Yes | No | Open repair; No fetal procedure | Yes (24 mos)
Total | 48 | 17, 38 | 3 of 3 | 1 of 3 | 23 of 3 | 2 of 3
Retrospective cohorts
Sinha et al.43 | 31 | 55 (no procedure) | Yes | No | No fetal procedure | No
Saura et al.41 2007 | 13 | 6 | Yes | No | No fetal procedure | Yes (6 mos)
Jani et al.35 2005 | 24 | 37 | Yes | No | No fetal procedure | No
Deprest et al.22 2004 | 21 | 17 | Yes | No | No fetal procedure | No
Keller et al.37 2003 | 16 | 40 | Yes | Yes | No fetal procedure | No
Total | 105 | 155 | 5 of 5 | 1 of 5 | 5 of 5 | 1 of 5
Prospective case series
Jani et al.36 2006 | 28 | NA | Yes | No | NA | No
Kohl et al.39 2006 | 8 | NA | Yes | Yes | NA | No
Total | 36 | NA | 2 of 2 | 1 of 2 | NA | 0 of 2
Retrospective case series
Peiro et al.44 2009 | 18 | NA | Yes | No | NA | No
Peralta et al.40 2008 | 30 | NA | Yes | No | NA | No
Heerema et al.33 2003 | 17 | NA | No | No | NA | No
Harrison et al.27, 32 1996, 2003 | 19 | NA | Yes | Yes | NA | Yes (40 mos)
Harrison et al.28 2001 | 2 | NA | Yes | No | NA | Yes (18 mos)
Flake et al.23, 42 2000, 2009 | 15 | NA | Yes | Yes | NA | Yes (24–48 mos)
Gibbs et al.24 1998 | 11 | NA | Yes | No | NA | Yes (48 mos)
Hubbard et al.34 1997 | 3 | NA | No | No | NA | No
Harrison et al.26 1993 | 14 | NA | Yes | No | NA | No (discharge)
Harrison et al.30 1990 | 6 | NA | Yes | No | NA | No
Total | 135 | NA | 8 of 10 | 3 of 10 | NA | 4 of 10

The 2003 randomized trial compared fetal tracheal occlusion to intervention at birth.29 Entry criteria for the trial included a lung-to-head measurement ratio (LHR) of less than 1.4, which in historical cohorts had resulted in a survival rate of less than 40 percent. Participants were randomized into strata of severity as indicated by this ratio. The endoscopic procedure was successfully carried out in 11 fetuses, two with a tracheal clip procedure and nine with an intra tracheal balloon procedure. The study was stopped after 24 participants because the findings revealed similar survival rates to 90 days of life: 73 percent for tracheal occlusion recipients and 77 percent for the group that did not receive fetal intervention, with no anticipation that continued study would be able to confirm statistically meaningful differences in outcomes in an acceptable timeframe. Infants in the treated group were delivered at a mean gestational age of 30.8 compared to a mean of 37.0 in the standard care group. Survival was significantly greater regardless of treatment group in infants with LHR >0.90. Consequently subsequent studies have focused on fetuses with LHR <1.0 predicting worse survival.

The fetal surgery trial group had higher rates of prematurity and lower birth weights. Follow-up of those infants has revealed more than half of both those with and without fetal treatment have growth failure and neurodevelopment status is not significantly different (Table 6). This study highlighted the importance of having a concomitant control group as the survival for CDH with postnatal repair had also improved over time from the predicted 38 percent, to 77 percent.

Table 6 Primary outcomes of maternal-fetal surgical procedures for congenital diaphragmatic hernia

Author, Year, Country | Comparison groups (N) | Key outcomes
Randomized trial
Cortes et al.21,29,38 2005 U.S. | G1: balloon tracheal occlusion (11) G2: no fetal procedure (13) | - Lung-to-head ratios <1.4 enrolled between 22 and 27 weeks’ gestation; - 8 of 11 (73%) occlusion recipients survived beyond 90 days; - 10 of 13 (77%) without fetal surgery survived; - Infants with occlusion were more likely to be born preterm; - Growth failure (<2 SDs below mean) occurred in 56% of controls and 86% of infants who had occlusion; - No neurodevelopmental differences at 1 or 2 years of age between groups
Prospective cohorts
Cannie et al.45 | G1: balloon tracheal occlusion (40) G2: no fetal procedure (18) | - No data about fetal deaths; does not include infants born before 32 weeks; - Fetuses with balloon occlusion had increase in lung volume in utero relative to untreated; - Earlier balloon occlusion (<29 weeks) was associated with greater increase in lung volume; - In multivariate models endoscopic occlusion was an independent predictor of survival
Harrison et al.31 1998 U.S. | G1: open tracheal occlusion (13) G2: fetoscopic occlusion (8) G3: no fetal procedure (13) | - All fetuses with isolated left CDH and poor prognosis; - 2 of 13 with open surgery survived to discharge; - 7 of 8 (88%) endoscopic occlusion recipients survived; - 5 of 13 (38%) without fetal surgery survived; - Endoscopic approach superior
Harrison et al.25 1997 U.S. | G1: open repair (4) G2: no fetal procedure (7) | - Repair at 25 weeks; - 3 of 4 (75%) with in utero repair survived; - 6 of 7 (86%) without fetal surgery survived; - Fetal surgery was associated with preterm birth: mean gestational age attained: 32 weeks for surgery; 38 weeks for no fetal surgery
Retrospective cohorts
Sinha et al.43 2009 U.K. | G1: balloon tracheal occlusion (31) G3: no fetal procedure (55) | - Balloon occlusion for fetuses with ratio ≤ 1.0; - Analysis includes only liveborn infants; - 16 of 31 (52%) with in utero repair survived neonatal course; - 35 of 55 (64%) without fetal surgery survived; - Lung-to-head ratio and best oxygenation index on first day of life were correlated with oxygenation status best predictor of survival
Saura et al.41 2007 Spain | G1: balloon tracheal occlusion (13) G2: no fetal procedure (6) | - Balloon occlusion done for fetuses with ratio <1.1; - Comparison group: 3 with ratio >1.4 and 3 without antenatal diagnosis; - 8 of 13 (61%) with occlusion survived; - 5 of 6 (83%) with good prognosis or no antenatal diagnosis survived
Jani et al.35 2005 Belgium | G1: balloon tracheal occlusion (24) G2: no fetal procedure (37) | - 12 of 24 (50%) with occlusion survived to 28 days of life; - The no fetal surgery group included 5 decisions for termination; - 3 of 32 (9%) without fetal surgery survived; - Fetal surgery reduced gestational age at birth with mean of 33 weeks
Deprest et al.22 2004 Belgium | G1: balloon tracheal occlusion (21) G2: no fetal procedure (17) | - Median gestational age at balloon placement: 26 weeks; - 10 of 21 (48%) with occlusion survived; - 11 of 12 (92%) without fetal surgery survived; - 5 cases ended in pregnancy termination
Keller et al.37 2003 U.S. | G1: balloon tracheal occlusion (16) G2: no fetal procedure (40) | - All fetuses with isolated left CDH and liver herniation and no other anomalies; - 11 of 16 (69%) with occlusion survived to discharge; - 17 of 40 (43%) of those without fetal surgery survived; - Calculation of lung-to-head ratio in CDH is a strong predictor of survival; above ratios of 1.0 risk of death plateaus

CDH=congenital diaphragmatic hernia; SD=standard deviation

Among the cohort studies of tracheal occlusion, survival ranged from 48 percent to 75 percent among treated fetuses and 8 percent to 65 percent among the untreated (Table 6), with the high end likely reflecting less severe disease. The sole well-documented exception to these ranges was the note that a favorable prognosis, as gauged by higher LHR (>1.1), had an 83 percent survival among the untreated.41 In that cohort there were no treated fetuses who did not have a ratio of less than 1, meaning they were all in the poor prognosis group.

Case series reflect the evolution of methods for treatment with consistent movement toward the improved outcomes observed in the cohorts and trials. In an initial report of eight fetuses using tracheal occlusion there was one survivor.27 The first attempt was done using a foam plug to occlude the trachea in two fetuses which caused tracheomalacia in the first and did not create enough of a seal in the second to prevent hypoplasia.27 In the same report, six subsequent fetuses were treated with a tracheal clip, all six delivered prematurely, and all died from complications of their disease or prematurity or a combination. Another series of 15 open procedures had 5 survivors, and studies of lung specimens suggested fetal lung growth increased but was not uniformly associated with normal tissue structure.23,42 Subsequent patient series added further experience that lead up to the trial.29

A number of recent case series reports from Europe and the United States have been published. Endoscopic placement of a specialized balloon originally designed for vascular embolization was reported in 18 of 21 unique publications. Occlusions in Europe are now often performed by obstetric groups with expertise in endoscopic treatment using a new generation of detachable balloons.39–41,43–45 Outcomes continue to trend toward favorable survival rates and lower risk of prematurity.

This literature has been focused primarily on short-term outcomes since congenital diaphragmatic hernia has such a high mortality. Long-term infant and maternal outcomes have been evaluated in few studies, with the longest followup of infant outcomes being between 24 months 21,25 and 48 months.23–24,27 Long-term maternal outcomes were addressed carefully in the early U.S. series, and future maternal fertility was documented in one series.30 For CDH, it is important to look at later outcomes since there is a significant postneonatal mortality reported in those groups that continue to follow their cohort.

All but one study provided good documentation of fetal inclusion criteria; only nine adequately described maternal inclusion criteria. The majority of studies did a thorough job of describing surgical approach. Though endoscopic devices are used, most of the procedures were done with a maternal laparotomy incision, often described as a minilaparotomy, prior to placement of trocars through the uterus. Open repairs were the primary use of full hysterotomy in 4 studies, and 6 of 21 papers described completely transcutaneous approaches. Use of both general and epidural anesthesia was common; some teams added fetal anesthesia and described their approach in publications; seven studies did not address anesthesia. A subset did not address details of the intraoperative and postoperative monitoring of mother and fetus; those that did were comprehensive and helpful in fully understanding the evolving standard of care. Outcomes assessed reflect lack of attention to longer term outcomes and maternal risks (Table 17).

Many questions remain including: What diagnostic approaches best predict prognosis? Which fetuses would benefit from treatment? When in gestation should the occlusive device be placed, and when in the gestation should the occlusive device be removed? The FETO Task group in Europe is using as a control group a multicenter study of 86 fetuses with left-sided CDH and liver herniation, which were managed expectantly and were live born after 30 weeks of gestation. In the control group, the survival rate increased from zero percent for those with LHR of 0.4 to 0.7 to about 15 percent for LHR of 0.8 to 0.9, 65 percent for LHR of 1.0 to 1.5, and 83 percent for LHR of 1.6 or more.46 This European series, which continues to add participants, has an 11 percent survival for LHR <1 and can serve as an ongoing reference point for expectations among untreated poor prognosis pregnancies in Europe as it is not possible to directly compare outcomes between Europe and the United States, given the difficulty in reconciling different postnatal survival rates.37 In the United States, multiple centers are working on device development or approval processes for an improved balloon to be used for tracheal occlusion.

Summary of congenital diaphragmatic hernia literature. Case reports comprise the bulk of the CDH literature and reflect movement toward improved outcomes for infants with CDH. The single randomized trial of in utero CDH therapy located for this review similarly reflects improved survival rates for fetuses treated with tracheal occlusion and infants treated at birth. Long-term outcomes, however, are not well reported, and significant questions about fetal treatment for CDH remain.

## State of the Science: Myelomeningocele/Spina Bifida

Background. Myelomeningocele (MMC) is a congenital malformation in which the meninges and spinal cord protrude through a defect in the vertebral arches, muscle, and skin. It is the most commonly observed malformation of the central nervous system, affecting more than 1,000 fetuses in the United States annually.47 MMC is the most common form of spina bifida, and although it is rarely fatal, individuals affected with it have a range of disabilities, including paraplegia, hydrocephalus, skeletal deformities, bowel and bladder incontinence, and cognitive impairment.

The standard treatment has been to close the defect postnatally, and shunting for hydrocephalus is common.

Animal research suggested that covering the defect early on could potentially result in better lower extremity and bladder function. Myelomeningocele repair was the first in utero surgery considered for a nonlethal malformation on the basis that its natural history was well known and leads to lifelong disability in the absence of intervention. Furthermore, the defect can be diagnosed prenatally in over 80 percent of cases by maternal serum alpha-fetoprotein and ultrasound; MRI is used to detect specific anomalies and disease process.

The procedure was initially performed by Bruner and colleagues as a closed laparoscopic covering of the spinal defect. The first case was reported in a letter, and a case series describing four fetuses was published in 1999 (the surgeries were conducted between 1994 and 1997).74 Half of the fetuses survived, and both survivors required shunting. In a continuation of this work, four fetuses were operated on using an open approach and compared to four done endoscopically,55 and the open surgery showed improved outcomes, while the endoscopic approach had high mortality. The endoscopic approach has been abandoned, and therefore the rest of this overview will focus on literature related to open surgery for MMC repair. Since 1997, more than 200 fetuses with MMC have undergone open surgical repair in the United States.

Included publications. Our search identified 27 publications48–74 that provided outcomes of surgery, two of which were on the use of endoscopic approach;55,74 these publications comprise 11 unique studies. These surgeries have taken place at four academic centers in the United States, but to date have not been in the context of a randomized controlled study (RCT). All nine analyses of open surgery are based on four series of patients, although varying study designs were used to analyze the data. For that reason, there are duplicate patients represented in different studies of publications as represented in Table 7. Where authors have presented serial groups of overlapping patients as case series have grown, we focus our discussion on the most complete set, but where there are subanalyses with specific comparisons, those are indicated.

Table 7 Summary of studies of maternal-fetal surgical procedures for myelomeningocele (MMC)

Author Year | With fetal procedure N | Without fetal procedure N | Fetal inclusion criteria provided? | Maternal inclusion criteria provided? | Comparison group | Outcomes beyond neonatal hospital stay?
Randomized clinical trials
None
Prospective cohorts
Tubbs et al.48– 49 2003 | 37 | 40 | Yes | No | No fetal procedure | Yes (36 mos)
Bruner et al.50 1999 | 29 | 23 | Yes | No | No fetal procedure | Yes (6 mos)
Retrospective cohorts
Danzer et al.51 2007 | 22 | 16 | No | No | No fetal procedure and age matched controls | No
Adelberg et al.52 2005 | 14 | 39 | Yes | No | No fetal procedure | No
Hamdan et al.53 2004 | 37 | 74 | No | No | Other preterm infants | No
Tulipan et al.54 2003 | 104 | 189 | Yes | No | No fetal procedure | Yes (>12 mos)
Bruner et al.55 2000 | 8 | -- | Yes | No | Endoscopic surgery | Yes (12 mos)
Prospective case series
None
Retrospective case series
Wilson et al.56–59,60,61–65 2007 | 54 | -- | Yes | Yes | NA | Yes (36 mos)
Bruner et al.66–71 2004 | 177 | | Yes | No | NA | Yes (36 mos)
Farmer et al.72–73 2003 | 13 | -- | Yes | No | NA | Yes (45 mos)
Bruner et al.74 1999 | 4 (endoscopic) | | Yes | No | NA | No
Grand total | 262 | 413 | 10 of 11 | 1 of 11 | | 8 of 11

(All patients represented in the total for retrospective cohorts except the Adelberg study are part of the series of patients totaled in the case series.)

Two studies, including overlapping patients from one center, had concurrent comparisons.48,50 The first study analyzed the first 29 cases of open MMC repair at Vanderbilt University Medical Center, and found significant reductions in the need for postnatal shunt placement (51 percent versus 91 percent; p=0.01) and reduced hindbrain herniation (38 percent versus 95 percent; p<0.001). However, the two prospective studies found greater rates of oligohydramnios among those with in utero repair (48 percent versus 4 percent; p=0.001), lower gestational ages in this group (33.2 weeks versus 37 weeks; p<0.001)50 and no difference in lower extremity function.48

Six retrospective cohort analyses were conducted,49,51–55 representing three patient populations. Of the five papers that included only open surgery, four used as their comparison group infants who had undergone postnatal repair.49,51–52,54 Again, substantially lower rates of postnatal shunt placement were observed (58 percent versus 92 percent) as well as lower incidence of hindbrain herniation (4 percent versus 50 percent).49 In a small series at one institution based on 14 repairs, no differences in ventricular progression were observed between the groups.52 Two of the academic centers with larger series combined their data and conducted the largest retrospective analysis.54 Although results of in utero repair were apparently positive in many of the prior studies, the question had been raised as to whether fetuses selected for in utero repair were fundamentally different than others in features affecting the risk of hydrocephaly, specifically lesion location. With this larger cohort, the investigators were able to stratify their results on lesion location and found statistically significant reductions in shunting relating to repairs of lumbar and sacral lesions, but not thoracic ones. They further observed an age effect whereby there was no improvement in fetuses whose repairs occurred after 25 weeks’ gestation, supporting the theory that early intervention is essential.54

Case series in these sets of patients showed results generally in line with the comparative studies described above, including rates of shunting about half those seen in postnatal repairs, reversal of hindbrain herniation, and positive rates of cognitive language and personal skills after 3 years (67 percent).53,56–71

Table 8 Primary outcomes of maternal-fetal surgical procedures for MMC

Author, Year, Country | Comparison groups, (N) | Key outcomes
Danzer et al.51 2007 U.S. | G1: in utero repair G2: postnatal repair G3: age-matched non-MMC patients | - In utero repair was associated with increased normalization of the posterior fossa CSF spaces; - Brain thickness was reduced in both pre- and postnatally repaired patients compared to age-matched comparators without MMC
Wilson et al.56–65 2007 U.S. | G1: in utero repair (58) | - 94% of fetuses survived, with a mean age at delivery of 34 weeks, 3 days; - 100% demonstrated reversal of hindbrain herniation; 43% required shunting; - Better than predicted leg function seen in 57% of thoracic and lumbar patients; - At 2 years of age, 30 returned for neurodevelopmental testing; - 67% had cognitive language and personal skills in normal range, 20% had mild delays and 13% has significant delays
Adelberg et al.52 2005 U.S. | G1: in utero repair (14) G2: postnatal repair (39) | - Study intended to measure ventriculomegaly in utero compared to that associated with postnatal repair; - No difference in ventricular progression was observed
Bruner et al.66,67–68,70–71 2004 U.S. | G1: in utero repair (177) | - 61/116 fetuses with 12 mos followup required shunt (54%); - Strongest predictor of shunt requirement was upper level lesion, followed by greater gestational age (>25 wks) and ventricular size of >14mm; - Among the first 95 infants, no difference in gestational age at delivery based on gestational age at repair (before or after 25 weeks); - Among 9 patients, ultrasound pre- and post- in utero repair showed reversal of preexisting hindbrain herniation
Hamdan et al.53 2004 U.S. | G1: infants born prematurely post in utero repair G2: infants born prematurely without MMC | - Rates of prematurity related complications (RDS, length of stay, IVH) were similar between infants born prematurely, post- in utero surgery and others without MMC born prematurely
Farmer et al.72,73 2003 U.S. | G1: in utero repair fetoscopic (3); open (10) | - 56% required shunt by one year compared to 90% in historical controls at the site; - 7 patients were examined for bladder function at 1 month; - Urodynamic patterns were similar to patients in other studies undergoing postnatal repair
Tubbs et al.48– 49 2003 U.S. | G1: in utero repair (37) G2: postnatal repair (40) | - No difference in lower extremity function between G1 and G2; - Substantially lower incidence of hindbrain herniation among in utero repair group compared to historical cohort of postnatal repair (4% vs. 50%)49; - Lower incidence of shunting in in utero repair group compared with historical postnatal repair group (58% vs. 92%)49
Tulipan et al.54 2003 U.S. | G1: in utero repair (104) G2: postnatal repair (189) | - Combined data from Vanderbilt Medical Center and Children’s Hospital of Philadelphia; - Statistically significant reductions in shunting at lumbar and sacral lesion levels, but not for thoracic lesions; - No statistically significant differences in fetuses older than 25 weeks gestation
Bruner et al.55 2000 U.S. | G1: endoscopic repair (4) G2: open (4) | - 2 survivors in the endoscopic group compared to 4 in the open surgery group; - Both survivors in the endoscopic group required shunting compared to 2 of 4 in the open surgery group
Bruner et al.50 1999 U.S. | G1: in utero repair (29) G2: postnatal repair (23) | - First 29 cases of open surgery at Vanderbilt Medical Center; - 51% of in utero cases required shunting compared to 91% of postnatal repairs (p=.01); - Reduced hindbrain herniation among in utero repairs (38% vs. 95%; p<.001); - Greater oligohydramnios among in utero repairs (48% vs. 4%; p=.001); - Gestational age for in utero patients 33.2 vs. 37 for postnatal repair patients (p<.001)
Bruner et al.74 1999 U.S. | G1: endoscopic repair | - 2 of 4 survived past 1 month after delivery

CSF=cerebrospinal fluid; IVH=intraventricular hemorrhage; MMC=myelomeningocele; RDS=respiratory distress syndrome

However, the procedure itself is not benign, and as with any surgery, the risk of maternal morbidity and mortality exists. Limited long-term data are available to assess maternal risks both in the immediate postoperative period and related to longer term fertility and none available in the studies that met inclusion criteria for this review. In addition, fetuses treated in utero routinely deliver prematurely, and outcomes related to prematurity may be the greatest challenge to evaluating the benefit of the surgical repair. Hamdan et al.53 found that rates of prematurity-related complications were no higher among infants born prematurely with MMC after in utero repair compared to those without MMC also born prematurely, suggesting that the procedure is not associated with worse side effects. Nonetheless, absent the in utero repair, patients with MMC could very well have delivered at term. These reasons combined with concerns that past study designs simply do not ensure comparable groups for analysis led the NIH to fund an RCT, which is currently ongoing. Known as the MOMS trial, this study is taking place at three of the centers whose work is represented in this section. The trial will enroll 200 mother-fetus pairs, and at this time, there is a voluntary moratorium in the United States on conducting in utero repair of MMC outside of the trial. Several of our key informants and experts in the literature75 suggested that this trial appropriately put a stop to a proliferation of centers doing in utero MMC repair based on enthusiasm but inadequate evidence.

Summary of the MMC literature. As is the case with other in utero repairs, evidence about MMC fetal surgical procedures from more rigorous studies is lacking; much of the MMC literature located for this review comprised retrospective cohorts and case series. Long-term followup of infants treated prenatally is limited, as are outcomes for mothers. No studies included in this review addressed long-term maternal fertility outcomes. Overall trends from cohorts and case series include reduced shunting after fetal surgical repair of MMC and positive rates of language development and personal skills after three years. The ongoing MOMS trial should augment the MMC evidence base and help to inform families’ and clinicians’ decisionmaking.

Addendum. As this report was in press, results from the Management of Myelomeningocele Study (MOMS) were published in the New England Journal of Medicine (February 9, 2011). The study’s findings add to the body of literature on maternal-fetal surgical procedures for myelomeningocele:

- The RCT reports results from 158 women participating between February 2003 and the trial’s early termination based on evidence for the efficacy of prenatal surgery in December 2010. Among these 158 participants, 78 were randomized to prenatal surgery before 26 weeks gestation and 80 to postnatal repair after cesarean delivery at 37 weeks (if undelivered).
- Primary outcomes included a composite of fetal or neonatal death or the need for cerebrospinal fluid (CSF) shunt (placement or meeting criteria for placement) at 12 months of life and a composite score on the Mental Development Index of the Bayley Scales of Infant Development II and motor function at 30 months.
- There were 2 deaths in each group (relative risk [RR], 95 percent confidence interval [CI]: 1.03, 0.14 to 7.10). Overall, 68 percent of prenatal group infants and 98 percent of postnatal group infants either died or required CSF shunt/met shunt criteria by 12 months (RR, 95 percent CI: 0.70, 0.58 to 0.84, p<0.001). Forty percent (n=31) of infants in the prenatal group and 82 percent (n=66) in the postnatal group required shunt placement (p<0.001).
- Composite scores on the Bayley Mental Development Index were significantly better in the prenatal group compared with the postnatal group (p=0.007); motor function and ability to walk without orthotics were also better in the prenatal group as were parent-reported self-care and mobility.
- Prenatal surgery was associated with higher rates of preterm birth, intraoperative complications, maternal transfusion, and uterine scarring. Rates of chorioamniotic membrane separation, spontaneous membrane rupture, and spontaneous labor were higher in prenatal surgery participants.
- Though the trial was stopped early by the study’s data safety monitoring board for positive results, the investigators note maternal and fetal risks including preterm delivery and uterine dehiscence.
- This RCT brings the total number of RCTs in the maternal-fetal surgery literature to four; it is the only randomized trial of assessing intervention for myelomeningocele. The study is of additional importance as a model for the field as investigators, working in collaboration with NIH, did not offer the procedure outside the trial during the duration of the study, helping to assure the feasibility of obtaining sufficient participants from around the country to obtain high quality data.

## State of the Science: Obstructive Uropathy

Background. A variety of fetal malformations can lead to distention of the urinary bladder; these include urethral atresia (failure of the bladder stem to properly form so urine cannot exit), posterior urethral valves (which in male fetuses can prevent flow of urine through the full length of the urethra); and megacystis-megaureter-microcolon syndrome (which results from malformation of the organs rather than frank blockage of urine flow), and prune-belly syndrome (which includes lack of development of abdominal muscles, undescended testicles, and urinary anomalies). Other urinary tract anomalies can result in distension of one or both ureters, such as blockage at the junction with the bladder or at any place along the ureter, which conveys urine from the kidney to the bladder. In this case when there is renal function and a ureteral impass, the distended portion of the urinary tract is the ureter or renal pelvis rather than the bladder.

Goals of fetal therapy have emphasized decompression rather than repair of the specific lesion. The goal of decompression of the distended portion of the urinary tract is to protect remaining renal function and to promote lung development. Challenges with increased preterm birth and comparable outcomes with open shunting procedures have resulted in a trend to percutaneous shunting procedures dominating the literature. After a small incision in the maternal skin, generally with local anesthesia only, the shunt is inserted through an introducer sheath into position within the fetal bladder. An internal guide or stylus within the shunt is withdrawn, allowing a prefabricated curl or “pigtail” to form at the distal end that helps hold the device within the fetal bladder. As the introducer is completely withdrawn, a second pigtail forms on the opposite end to hold the shunt outside the fetus and to assure drainage of urine into the amniotic cavity. When the shunt type or method was noted by authors to vary from this, we have indicated the difference.

Included publications. Our search indentified 26 publications representing 25 unduplicated reports about fetal interventions for obstructive uropathy. The publication that duplicates the same study population76 is superceded in this summary by the original report.77 We did not include reports that only focused on vesicocentesis, because this approach does not reach the degree of complexity to be considered a fetal surgical procedure and is most often reported as a diagnostic procedure to gauge renal function to inform decisions about choice of therapy. We recognize that the 25 identified publications include duplication of individual mothers and babies.

Table 9 Summary of studies of maternal-fetal surgical procedures for obstructive uropathy

Author Year | Shunt procedure N | Without this fetal procedure N | Fetal inclusion criteria? | Maternal inclusion criteria? | Comparison group | Outcome beyond neonatal stay?
Randomized clinical trials
None
Prospective cohorts
Welsh et al.78 2003 | 3 | 10 | Yes | No | Hydroablation and/or guidewire passage | Yes
Quintero et al.79 1995 | 6 | 7 | Yes | No | No fetal procedure (6); disruption of PUV (1) | No
Johnson et al.80 1994 | 15 | 8 | Yes | No | No fetal procedure | Yes (18–66 mos)
Total | 24 | 25 | 3 of 3 | 0 of 3 | 2 of 3 include no treatment | 2 of 3
Retrospective cohorts
Salam et al.81 2006 | 12 | 46 | Yes | No | No fetal procedure | Yes (mean 47 mos)
Wilson et al.82 2003 | 3 | 3 | No | No | No fetal procedure | No
Warne et al.83 2002 | 2 | 4 | No | No | No treatment (All had suspected cloacal anomalies) | Yes (poorly specified)
Holmes et al.84 2001 | 9 | 5 | No | No | Bladder marsupialization (2); ablations of PUV (2); cutaneous ureterostomy (1) | Yes (mean 139 mos)
McLorie et al.85 2001 | 9 | 3 | Yes | No | No fetal procedure | Yes (mean 42 mos)
Freedman et al.86 1996 | 28 | 27 | Yes | No | No fetal procedure | No
Crombleholme et al.87 1990 | 19 | 21 | Yes | No | No fetal procedure | No
Harrison et al.77 1982 | 5^*^ | 21 | Yes | No | No fetal procedure | Yes (ad hoc)
Total | 87 | 130 | 5 of 8 | 0 of 8 | 7 of 8 include no treatment | 5 of 8
Prospective case series
Araujo et al.88 2007 | 13 | NA | Yes | No | NA | No
Craparo et al.89 2007 | 12 | NA | Yes | No | NA | Yes (3–36 mos)
Biard et al.90 2005 | 31 | NA | Yes | No | NA | Yes (70 mos)
Makino et al.91 2000 | 5 | NA | Yes | No | NA | Yes (0–48 mos)
Freedman et al.92 1999 | 14 | NA | Yes | No | NA | Yes (54 mos)
Evans et al.93 1991 | 3 | NA | Yes | No | NA | Yes (3–36 mos)
Manning et al.94 1986 | 73 | NA | No | No | NA | No
Total | 151 | NA | 6 of 7 | 0 of 7 | NA | 5 of 7
Retrospective case series
Gehring et al.95 2000 | 3 | NA | No | No | NA | No
Shimada et al.96 1998 | 6 | NA | No | No | NA | Yes (1–14 mos)
Pinckert et al.97 1994 | 2 | NA | No | No | NA | Yes (2–4 mos)
Bernaschek et al.98 1994 | 13 | NA | No | No | NA | No
Robichaux et al.99 1991 | 2 | NA | No | No | NA | No
Crombleholme et al.100 1988 | 5 | NA | No | No | NA | Yes (24–36 mos)
Manning et al.101 1983 | 2 | NA | Yes | No | NA | Yes (6 mos)
Total | 33 | NA | 1 of 7 | 0 of 7 | NA | 4 of 7

PUV=posterior urethral valves

* Varied therapeutic approaches (vesicoamniotic shunt, transcutaneous catheter drainage, hysterotomy with repair)

Of the 25 publications, 13 originate from research in the United States;77,79–80,84,86–87,90,92–93,95,97,99–100 4 from Europe;78,83,89,98 3 from Canada,82,85,101 2 from Japan,91,96 and 1 each from Egypt,81 Brazil,88 and the International Fetal Surgery Registry.94

Three publications were prospective cohorts;78,80,94 eight were retrospective cohorts;77,81–87 seven were prospective case series;88–94 and seven were retrospective case series.95–101

Prospective cohorts. Among the three prospective cohort studies,78,80,94 none restricted to a single underlying pathology. Two groups78–79 performed in utero cystoscopy to evaluate the urinary outflow tract and bladder. Each performed some maneuvers to attempt to establish patency of the urethra when applicable. One group placed transurethral shunts when possible during the cystoscopy79 and the other used cystoscopy in a phased process in which recurrence or persistence of obstruction was the indication for subsequent shunt placement.78 Another publication reports the predictive value of urinary electrolyte and protein analysis obtained by vesicocentesis as a prognostic guide to likely disease severity; some fetuses with both poor and good prognosis (based on their hypothesis) received shunts.80

In total (Tables 13 and 14), 24 fetuses had placement of shunts in these studies; 11 had hydroablation or other disruption of posterior urethral valves (PUV); 14 fetuses had no fetal intervention; and another 13 pregnancies were terminated given clinical assessments of very poor prognosis. Overall, 53 percent to 66 percent of infants who had shunt placement survived short term (Table 10). Long-term data is scant and no longer than early childhood (Table 10). Prognosis was most easily established for dire cases without urine production and with poor lung development. For cases in which there was fetal urine production, diagnostic testing of fetal urine did not cleanly segregate those who would do well without intervention or the outcomes of intervention. The range of sensitivity for urine markers for predicting “absence of significant underlying renal damage” from last urine specimen obtained was 0.88 to 1.00; specificity ranged from 0.47 to 0.84, with positive predictive values between 0.47 and 0.77.^102^ From another vantage point, ability to predict absence of renal dysplasia from urine markers in a related study was reported with sensitivity 0.17 to 1.00, specificity 0.27 to 0.91, and positive predictive value 0.43 to 1.00.^80^ Small sample sizes significantly limit the ability to draw definitive conclusions, but it is helpful to have those cases that received no fetal intervention, or who had alternate interventions, receiving the balance of their care within similar protocols in the care of the same providers. These studies also provide evidence of feasibility of fetal cystoscopy for diagnostic evaluation and in some cases direct treatment of obstruction.

Table 13 Summary of cohort and case series studies of maternal-fetal surgical procedures for thoracic lesions

Author Year | With fetal shunting N | Without this procedure N | Fetal inclusion criteria? | Maternal inclusion criteria? | Comparison group | Outcomes beyond neonatal hospital stay?
Cohorts
Morris et al.127 2009 | 3 shunt 3 open | 38 | Yes | No | High risk lesion without surgery (7) All types of lesions who received steroids (9) | Yes (≥5 mos)
Merchant et al.125 2007^*^ | 9 | 19 | Yes | No | Ineligible for fetal surgery (13); matched no fetal surgery (6) | Yes (1.5–9 mos)
Grethel et al.110 2007^*^ | 9 | 154 | Yes | No | No fetal surgery (129); open fetal surgery (25) | Yes (1 mos)
Morikawa et al.126 2003^*^ | 2 | 2 | Yes | No | No fetal surgery (2) | Yes (24–36 mos)
Adzick et al.24,117,120–124 1998^*^ | 6 | 114 | Yes | No | No fetal surgery (101); open fetal surgery (13) | Yes (12–84 mos)
Adzick et al.120 1998 | 2 | 1 | Yes | No | No fetal surgery | No
Dommergues et al.118–119 1997^*^ | 9 | 17 | Yes | No | No fetal surgery | Yes (5–36 mos)
Becmeur et al.130 1997 | 1 | 9 | Yes | No | No fetal surgery | No
Total | 44 | 354 | 8 of 8 | 0 of 8 | 8 of 8 include no fetal surgery | 6 of 8
Case series
Araujo et al.88 2007^*^ | 2 | NA | Yes | No | NA | No
Wilson et al.128 2004^*^ | 10 | NA | Yes | No | NA | No
Golaszewski et al.129 1998^*^ Bernaschek et al.98 1994^*^ | 4 | NA | Yes | No | NA | Yes (mean 30 mos)
Total | 16 | NA | 3 of 3 | 0 of 3 | NA | 1 of 3

* CCAM studies

Table 14 Primary outcomes of maternal-fetal surgical procedures for thoracic lesions

Author, Year, Country | Comparison groups (N) | Key outcomes
Prospective cohorts: CCAM
Dommergues et al.118 1997 Revillon et al.119 1993 France | G1: thoracoamniotic shunt (9) G2: no fetal procedure (17) | - All 9 fetuses receiving thoracoamniotic shunt were hydropic; - All 17 fetuses in no fetal surgery group were nonhydropic; - 5 of 9 (55%) fetuses receiving thoracoamniotic shunt died; all had pulmonary hypoplasia at autopsy; - 1 patient had PROM within 48 hours of shunt placement and delivered at 31 weeks (infant died); - 3 of 12 pregnancies assigned to receive thoracoamniotic shunt terminated the pregnancy; - 17 of 17 nonhydropic fetuses assigned to no fetal surgery group survived; - 11 of 17 (65%) of no fetal surgery cases the lesion was < 50% of the thorax; - 11 of 17 of infants in no fetal surgery group had to undergo postnatal surgery
Retrospective cohorts: CCAM
Morris et al.127 2009 | G1: open fetal surgery (3) G2: thoracoamniotic shunt (3) G3: High risk no procedure (7) | - 3 of 3 fetuses with open fetal surgery died intraoperatively or in utero; - 2 of 3 with thoracoamniotic shunt survived; - 4 of 7 infants with hydrops survived without prenatal intervention; - 4 of 4 survivors without procedure responded well to prenatal steroids; 3 who died did not respond
Adzick et al.120–122 1998, 1994, 1993 Cha et al.123 1997 Kuller et al.124 1992 Harrison et al.117 1990 Gibbs et al.24 1998 U.S. | G1: thoracoamniotic shunt (6) G2: open fetal lobectomy (13) G3: no fetal procedure (101) | - 3 of 3 nonhydropic fetuses survived after shunt placement, with 1 requiring ECMO for 4 days and 1 requiring high-frequency ventilation for 2 weeks; - 2 of 3 (66%) hydropic fetuses survived after shunt placement; - 8 of 13 (62%) fetuses undergoing open fetal lobectomy survived at up to 7 years follow-up; - Mean postoperative pregnancy duration was 8 weeks (range: 2–13 weeks); - 76 of 101 fetuses in the no fetal surgery group did not have hydrops; 100% survived (66 of 76 received postnatal resection); - 25 of 101 fetuses in the no fetal surgery group were hydropic; 100% died; - 4 of 4 infants who had open fetal surgery had normal neurodevelopment at up to 47 mos
Grethel et al.110 2007 U.S. | G1: thoracoamniotic shunt (9) G2: open fetal procedure (25) G3: no fetal procedure (129) | - 5 of 9 (45%) fetuses who received thoracoamniotic shunt survived (1 of 5 with hydrops survived); - 14 of 25 (56%) who had open fetal surgery survived (13 of 23 with hydrops survived); - 113 of 129 (87%) who were in the no fetal surgery group survived (0 of 14 with hydrops survived)
Retrospective cohorts: CCAM
Merchant et al.125 2007 U.S. | G1: thoracoamniotic shunt for macrocystic CCAM (9) G2: no fetal surgery-CCAMs did not require prenatal shunt (13) G3: gestation, volume, and CVR-matched CCAM who did not require prenatal shunt (6) | - All infants underwent surgical resection of CCAMs within first month of life; - G1: 2 of 9 (22%) had significant chest wall deformity with rib deformity and rib thinning; 2 of 9 had rib fractures; - G2: 13 of 13 had normal chest radiographs immediately after resection of CCAM without rib deformity, thinning, or fractures; - G3: 2 of 6 had no rib deformity on chest radiographs; 4 of 6 had symmetric, minimal rib thinning
Morikawa et al.126 2003 Japan | G1: thoracoamniotic shunt (2) G2: no fetal procedure (2) | - G1: 2 of 2 infants survived and were well at 2 yrs; - G2: 2 of 2 infants survived and were well at 2 and 3 yrs; - G1: Gestational age was 37–40 weeks; - G2: Gestational age 30–37 weeks; - All 4 infants underwent postnatal surgery for CCAM
Retrospective cohorts: BPS
Adzick et al.120 1998 U.S. | G1: thoracoamniotic shunt (2) G2: no fetal procedure (1) | - 2 of 2 infants with thoracoamniotic shunt survived but required ventilator support and postnatal extralobar pulmonary sequestration resection; - 1 infant without fetal surgery was diagnosed at 34 weeks’ gestation and died of pulmonary hypoplasia after postnatal resection and ECMO for 3 weeks
Becmeur et al.130 1997 France | G1: pleuro-amniotic shunt (1) G2: no fetal procedure (9) | - 1 infant received pleura-amniotic shunt at 30 weeks gestational age; - 6 of 9 infants who received no fetal surgery had absolute or relative regression of the thoracic mass; - Definitive diagnosis of BPS was done after birth (9) by MRI or US; - 8 of 10 infants had other congenital malformations
Case series: CCAM
Araujo et al.88 2007 Brazil | G1: thoracoamniotic shunt (2) | - 2 of 2 fetuses survived to one week of age
Wilson et al.128 2004 U.S. | G1: thoracoamniotic shunting (10) | - 7 of 10 (70%) infants survived; - 2 of 10 (20%) infants died during the neonatal period; - 1 of 10 fetuses died in utero; - 6 of 10 fetuses were hydropic; - 5 of 10 fetuses had polyhydramnios; - 3 fetuses had both hydrops and polyhydramnios; - All survivors had resection of CCAM in first 3 days of life
Golaszewski et al.129 1998 Bernaschek et al.98 1994 Austria, Germany | G1: thoracoamniotic shunting (4) | - 0 of 4 fetuses died in utero; - 3 of 4 (75%) infants survived the perinatal period; - 1 of 4 delivered preterm; - 1 of 4 infants had occlusion of the shunt 1 week after shunt placement and required thoracocentesis four times in 10 days

BPS=bronchopulmonary sequestration; CCAM=Congenital Cystic Adenomatoid Malformation; ECMO=Extracorporeal Membrane Oxygenation; MRI=Magnetic Resonance Imaging; PROM=Preterm rupture of membranes; US=ultrasound

Table 10 Primary outcomes of maternal-fetal surgical procedures for obstructive uropathy

Author, Year Country | Comparison groups, (N) | Key outcomes
Prospective cohorts
Welsh et al.78 2003 U.K. | G1: vesicoamniotic shunt after attempted hydroablation (3) G2: hydroablation and/or guidewire passage through cystoscope (7) | - 2 of 3 (66%) shunt recipients survived to infancy; - 1 had normal kidney function, 1 poor function at 22 months; - 1 of 3 died of complications of preterm premature rupture of membranes at 22 weeks; - 6 hydroablation/guidewire procedures achieved technical success/patency of the bladder outlet; - 4 of 7 (57%) survived to infancy; 1 pregnancy was terminated; 1 miscarriage (20 weeks), and 1 IUFD
Quintero et al.79 1995 U.S. | G1: vesicoamniotic shunt (6) G2: no fetal procedure (7) | - Fetal cystoscopy was possible in 11 of 13 cases, patency established in 1 case; - 2 transurethral vesicoamniotic shunts placed; - 4 of 6 (66%) shunt recipients survived to hospital discharge; - 1 pregnancy terminated after shunt; - Of the four survivors with shunts, no data is available about renal function at birth or longer term outcomes
Johnson et al.80 1994 U.S. | G1: vesicoamniotic shunt (15) G2: no fetal procedure (8) | - 8 of 15 shunt recipients (53%) survived to infancy; - 3 deaths (one in utero) among those with good antenatal prognosis prior to shunt; 4 among those with poor prognosis; - Among the 8 fetuses observed, 3 had resolution of obstruction and survived (38%) and 5 died in utero; - Those shunted had better prognosis based on urinary analysis of fetal renal function; - During evaluation, prior to decisions about intervention options, 11 pregnancies were terminated; 10 confirmed to have advanced renal fibrosis and dysplasia cloacal dysgenesis at autopsy
Retrospective cohorts
Salam et al.81 2006 Egypt | G1: vesicoamniotic shunt for PUV (12) G2: no fetal procedure (46) | - 8 of 12 (66%) shunt recipients survived; - 1 of 8 had renal insufficiency, 3 had renal failure and are transplanted or candidates; - Comparison group reflects infants who survived to receive postnatal treatment; survival cannot be calculated; - 43 of 46 (93%) infants treated achieved normal renal function after treatment of PUV; - Urodynamic findings for those with antenatal vs. postnatal treatment
Wilson et al.82 2003 U.S. | G1: vesicoamniotic shunt for PUV (3) G2: other (not defined) (3) | - Therapy not sufficiently specified to distinguish outcomes across groups; - 4 infants survived and one had renal failure
Warne et al.83 2002 U.K. | G1: vesicoamniotic shunt (2) G2: no fetal intervention (4) | - All fetuses had suspected cloacal anomalies; - All survived; - 2 of 2 shunt recipients survived to birth; - 1 of 2 had renal failure
Holmes at al.84 2001 U.S. | G1: vesicoamniotic shunt for PUV (9) G2: bladder marsupialization (2) G3: ablations of PUV (2) G4: cutaneous ureterostomy (1) | - Outcomes are primarily grouped across all interventions; - 5 of 14 (36%) infants died in utero; 1 pregnancy was terminated; - 8 of 14 survived (57%) into childhood; - 5 of 8 survivors had renal disease; 2 of those five had transplants, 1 was awaiting transplant
McLorie et al.85 2001 Canada | G1: vesicoamniotic shunt for PUV (9) G2: no fetal procedure (3) | - 6 of 8 (75%) shunt recipients survived into childhood; 1 pregnancy terminated after shunting; - None of the untreated infants survived to follow-up; - 5 of 6 survivors had growth in childhood less than 50% height and weight for age; - 2 of 6 had long term pulmonary sequelae; - 3 of 6 had renal impairment; 2 received transplants
Freedman et al.86 1996 U.S. | G1: vesicoamniotic shunt (28) G2: no fetal intervention (27) | - 17 of 28 (61%) shunt recipients survived to discharge; - 3 of 17 (18%) survivors post shunt had end stage renal disease and 2 had renal impairment; - 5 of 27 (19%) without fetal surgery survived; - 1 of 5 survivors without surgery had renal impairment
Crombleholme et al.87 1990 U.S. | G1: shunt in good prognosis group (9) G2: no fetal procedure in good prognosis group (7) G3: shunt in poor prognosis group (10) G4: no fetal procedure in poor prognosis group (14) | - 8 of 9 (88%) shunt recipients in the good prognosis group survived hospital course, 1 pregnancy terminated; - 5 of 7 without surgery and good prognosis survived; - 3 of 10 (30%) shunt recipients in the poor prognosis group survived; - Poor prognosis group without surgery included 11 terminations and 3 fetal or neonatal deaths; - In the short term among those with good prognosis, 2 untreated infants have renal insufficiency and none of the shunted infants had renal impairment
Harrison et al.77 1982 U.S. | G1: no fetal procedure good prognosis (14) G2: decompression with equivocal prognosis (3) G3: no fetal surgery with equivocal prognosis (4) G3: decompression with poor prognosis (5) G3: no fetal procedure poor prognosis (3) | - 14 of 14 with good prognosis and no fetal intervention survived to birth; - 2 of 3 (66%) with decompression and equivocal prognosis survived; one with renal disease; - 4 of 4 with equivocal prognosis and no fetal surgery survived; two with renal disease; - 2 of 5 (40%) with poor prognosis and intervention to decompress the outflow tract died, 3 pregnancies were terminated (no survivors); - 3 of 3 with poor prognosis and no surgery died; - Infants with unilateral ureteral obstruction did well without intervention, 8 of 8 survived with normal renal function
Prospective case series
Araujo et al.88 2007 Brazil | G1: vesicoamniotic shunt (13) | - 3 of 13 (23%) required replacement of shunt because the device did not remain properly placed (1) or obstruction was suspected (2); - 1 of 13, a fetus with trisomy 21, died in utero; - 12 of 13 survived to one week of age
Craparo et al.89 2007 Italy | G1: vesicoamniotic shunt (12) | - 2 fetuses never re-accumulated amniotic fluid and pregnancies were terminated, both found to have renal dysplasia; - 10 of 10 remaining reaccumulated fluid, all survived to discharge; - Followup ranged from 3 months to 3 years; - 6 had kidney failure with transplant or pending transplant; 4 had normal kidney function
Biard et al.90 2005 U.S. | G1: vesicoamniotic shunt (31) | - 8 of 31 were lost to followup; - 23 of 23 live births in the group identified and followed; - 21 of 23 (91%) survived to 1 year of age; 2 deaths from pulmonary hypoplasia; - Average followup 5.8 years: 12 of 18 with data failure to thrive; 8 of 18 abnormal pulmonary function; 9 of 18 musculoskeletal conditions; - 8 of 18 normal renal function; 6 of 18 required transplantation; - 11 of 18 (61%) had normal bladder function; - Self-reported health-related quality of life was comparable to healthy children
Makino et al.91 2000 Japan | G1: vesicoamniotic shunt (5) | - 2 of 5 (40%) survived; - 1 survivor had hydrocephalus and normal renal function, the other had a seizure disorder; - Both had developmental delay of unclear relation to obstructive syndrome
Freedman et al.92 1999 U.S. | G1: vesicoamniotic shunt (14) | - This paper included outcomes for 14 of 17 members of case series who are more than 2 years old; - 3 were lost to follow-up or declined participation; - 4 of 14 had pulmonary conditions; 6 of 14 did not have normal voiding function; 3 had renal insufficiency and 5 had renal failure; - 3 of 14 had bladder augmentation surgeries
Evans et al.93 1991 U.S. | G1: vesicoamniotic shunt | - 1 child with normal renal function at age 3; - 1 child with normal renal function and deafness at 3 months; - Scheduled shunt placement was not required, decompression resolved megacystis and did not recur
Manning et al.94 1986 Multinational | G1: vesicoamniotic shunt (73) | - 30 of 73 (41%) survived; - Procedure-related death rate was 4.6%; - 11 pregnancies were terminated; - Pulmonary hypoplasia (27) leading cause of death
Retrospective case series
Gehring et al.95 2000 U.S. | G1: vesicoamniotic shunt (3) | - Reports a series of infants with abdominal wall hernia after shunt above the umbilicus; hernias repaired at birth; - 2 of 3 required dialysis
Shimada et al.96 1998 Japan | G1: vesicoamniotic shunt (6) | - Infants entered this series at birth; - 4 of 6 had normal pulmonary function; - 5 of 6 had abnormal voiding function, including after surgical procedures; - 4 of 6 had normal renal function; - 2 of 6 had mild to moderate mental retardation
Pinckert et al.97 1994 U.S. | G1: vesicoamniotic shunt (2) | - 1 with peritoneal and nephrostomy shunts had normal growth and normal renal function at 4 months of age; - 1 with nephrostomy had abnormal renal function at 2 months of age
Bernaschek et al.98 1994 Multinational | G1: vesicoamniotic shunt (13) | - 7 of 13 (54%) survived; - 1 of 13 died in utero, 1 terminated pregnancy, and 2 died in neonatal period; - 29 vesicoamniotic, thoracoamniotic, pleuroamniotic, or abdominoamniotic shunts (for a broader range of conditions included in aggregate in paper) required shunt replacement; - Procedure-related mortality was 8%
Robichaux et al.99 1991 U.S. | G1: vesicoamniotic shunt (2) | - Reports cases of infants with abdominal wall hernia after shunt; - Both had paramedian abdominal defects repaired at birth
Cromblehome et al.100 1988 U.S. | G1: open surgery (5) | - All open fetal surgery cases; - 2 of 5 died at birth from pulmonary hypoplasia; - 1 of 3 survivors had renal failure requiring transplant
Manning et al.101 1983 Canada | G1: vesicoamniotic shunt (2) | - 1 infant survived and had normal renal function at 6 months of age; - 1 infant died of pulmonary hypoplasia within an hour of preterm birth at 30 weeks

IUFD=intrauterine fetal death/in utero fetal demise; PUV=posterior urethral valves

Each group reported on fetal eligibility criteria, none reported maternal inclusion criteria, none reported the approach to maternal anesthesia or analgesia, and none, other than noting ultrasound guidance, provided information about the monitoring of fetal well-being during or immediately after the procedure. One report80 noted that 6 of 15 shunt placements required a second procedure to replace the shunt, while others did not comment on this aspect of care. Maternal complications were not systematically documented, and infections were only noted in the context of reasons for poor fetal outcomes on a case-by-case basis, such as noting that an infant died in utero secondary to chorioamnionitis. The status of renal function and need for transplant was well documented in these prospective cohorts, though duration of followup was varied within studies and overall limited. In contrast, pulmonary status was noted by only one report,80 and neonatal and early childhood developmental status was not addressed in any of the publications. Table 17 summarizes the outcomes assessed by procedure type.

Retrospective cohorts. Eight studies77,81–87 reported on cohorts from clinical medical or fetal surgery program records. One study reports on the urological outcomes of infants known to have been shunt recipients who presented for urologic care in infancy and for whom the denominator of total shunt recipients is unknown so direct comparisons to surgical cohorts are inappropriate.81 All retrospective cohorts have small number of treated fetuses (2 to 28) and small comparison groups (3 to 46), with a total of 87 shunt recipients and 130 comparison group members in the eight cohorts. With one exception composed of small numbers of varied surgical approaches,84 the comparison groups are affected pregnancies without fetal intervention.

Short-term survival to birth and/or hospital discharge ranged from 30 percent in a poor prognosis group, to 88 and 100 percent in the good prognosis group, and 57 to 75 percent for typical obstructive conditions not stratified by risk (Table 10). In the sole cohort of female infants with cloacal anomalies, both infants who had a shunt placed survived.83 A commonality across studies is that survival is not a sign that risk of renal compromise is low. Risk of renal compromise is 31 percent across all retrospective cohorts, with the majority of smaller cohorts closer to 50 percent (Table 10). Among those infants with renal compromise the plurality progressed to dialysis and transplant. The exceptions were noted early in the history of fetal intervention of obstructive urinary tract conditions—fetuses with unilateral ureteral obstruction do well without intervention, and the majority have normal renal function after postnatal intervention.77 and infants with clusters of concomitant anomalies fare worse than those with isolated obstructive conditions.

Five of eight studies described the fetal eligibility criteria used to determine appropriateness for shunt placement; none reported use of any maternal eligibility restrictions. A subset of studies in this group have longer follow-up, one to an average of 11 years.84 Three studies do not follow infants past the initial neonatal admission, and two studies poorly specify whether there was a systematic effort to achieve followup through a specific time in childhood; thus it is difficult to know if complete ascertainment of outcomes was obtained (Table 10). No single study in this group was large enough to conduct multivariable analysis to adjust for candidate confounders or modifiers of treatment outcomes; and in aggregate the number of participants would fall short of that needed for meta-regression.

No studies reported maternal inclusion criteria or outcomes in a systematic fashion. One study described the type of anesthesia of analgesia provided for procedures,77 and no studies reported on monitoring of fetal well-being during or immediately after procedures beyond ultrasound during the procedure and to check shunt location and obstruction status after procedures. All studies reported on survival to birth and into infancy; seven of eight make note of preterm births and complications associated with prematurity; all make some note of assessment of renal function, and four of eight note pulmonary morbidity and sequelae. Pulmonary outcomes were overwhelmingly those close to birth, such as duration of ventilation. In individual cases, chronic pulmonary dysfunction was noted, but these assessments did not have any apparent uniformity. No retrospective studies had access to information about neurologic status in the neonatal period or later; and a single study reported that half of infants with a history of obstructive uropathy had abnormal growth patterns (diminished height and weight) into childhood.85

Prospective case series. Seven studies88–93 including the report from the International Fetal Surgery Registry,94 gathered prospective data about 151 treated fetuses, of which 73 were registry cases. Short-term survival ranged from 100 percent in a single report of 3 cases,93 92 percent in the Brazilian series of 13 cases;88 and 91 percent in a larger U.S. series.90 However, in that U.S. series, eight infants were lost to followup. Other groups reported less uniformly positive outcomes with survival in 83 percent,89 62 percent,92 and 40 percent91 among infants treated by vesicoamniotic, nephrostomy, or ureteral shunt placement. Need for shunt replacement was only reported by one paper, in which 23 percent of ongoing pregnancies required another procedure. The registry, which reflected care at 20 centers, reported 41 percent survival to birth with a 4.6 percent procedure-related death rate. This number takes into account pregnancy terminations that resulted after failure of the shunt to improve amniotic fluid volume and lung development. If terminations were not counted, the survival rate would be 48 percent.

Two larger studies focused on followup in childhood,90,92 with findings consistent with those of smaller reports: shunted infants are at risk of poor growth in infancy; 34 percent to 40 percent will have severe renal disease and require dialysis and transplantation; one-quarter to nearly half do not have normal voiding function, with need for catheterization remaining common even after urologic surgery; one-third to half have pulmonary conditions; 25 percent have recurrent pulmonary infections, and 25 percent have asthma controlled by inhalers. The majority of children will have one or more surgeries for the condition that caused the obstruction. Among 14 parent-child pairs who completed health-related quality of life surveys, the scores were comparable to those of healthy children, suggesting children and families accommodate well to the challenges.90

While six of seven studies reported the criteria by which fetuses were selected for intervention, none reported maternal characteristics or eligibility criteria to allow assessment of whether the population of participants was similar to another setting or country. Two studies noted that local anesthesia was used; others did not provide details. None reported beyond ultrasound guidance on the protocol for fetal monitoring during or immediately after the procedure. No studies noted any information about maternal outcomes beyond route of delivery.

Retrospective case series. Seven studies95–97,99–101 and one report from multiple European sites98 gathered data retrospectively. Two are reports of abdominal wall hernias as a complication of shunt placement. These papers summarized outcomes for five infants, all of whom had repair of the defect at birth; other outcomes information is not the focus of these reports.95,99 The remaining five case series include the early reports of these procedures including initial attempts to define prognostic factors and protocols to select and care for pregnancies complicated by fetal obstructive uropathy. In total, these 5 publications report on 28 infants.

Reported survival was 50, 58, 60, and 100 percent, the last among two cases (Table 10). One of the studies began tracking infants at birth and cannot provide survival data. The studies are concordant with later and larger reports: shunt replacement is common; outcomes of open surgery were similar to percutaneous in a study with five cases; and residual renal impairment and need for dialysis and transplant is common. Details about infant status and childhood are the most limited in this literature. Likewise, details about inclusion criteria and content of care is typically narrative by case, variable, and difficult to compile as is common for case reports.

Summary of obstructive uropathy literature. Positive trends in this literature include larger numbers of participants and increasing momentum from small case series to larger cohorts that include fetuses that received intervention(s) and those that did not. Because the initial reports were in the early 1980s, and nearly a decade was spent in establishing which fetuses might be most likely to benefit, the literature does not yet include detailed comparative followup studies.

Across study designs common elements emerge: those fetuses who present later in gestational age with very little or no amniotic fluid, or those who have no urine production and/or with no lung development are not targets of intervention. With such restrictions, survival is enhanced but far from certain with 50 percent to 88 percent of treated fetuses surviving, and prognosis not predictable with confidence even among those fetuses who can be salvaged. Fetal intervention may not always change the long-term prognosis of renal function; sequelae of posterior urethral valves may not be preventable.84 Projections of prognosis are further hindered because though karyotyping is generally required, a proportion of affected infants have clusters of syndromic features that are not readily diagnosed antenatally with confidence and that, when combined with renal or pulmonary compromise, have a synergistic effect in increasing mortality risk and amplifying morbidity experienced among survivors. More than one-third of otherwise normal infants who have only isolated bladder outlet tract obstruction and do not have multiple anomalies or syndromes do not recover normal renal function in childhood, and the majority of those with impaired renal function require dialysis and renal transplantation.

Critical gaps in the literature include complete lack of randomized trials among the groups in which there is clinical uncertainty, including lack of randomized trials making direct comparisons. Studies should continue to enhance description of fetuses enrolled, and must begin to present information about maternal characteristics and selection. Furthermore, multiple key informants expressed concern that intervening for obstructive uropathy may be seen as an “easy” in utero intervention and that therefore it may be escaping into practice in the absence of adequate evidence, methods for selecting patients, or training of physicians. They stressed the need for research and training around identifying appropriate surgical candidates. Finally, patient selection criteria should be carefully assessed and potentially updated.

Systematic and uniform assessments of early neurologic and health outcomes associated with critical illness and prematurity must be tracked, such as risk of ventricular hemorrhage and oxygen dependence. These need be extended to use of reliable tools for uniform assessment of growth and development in childhood. Given the importance of pulmonary sequelae as an outcome, it is quite concerning that little is known about pulmonary outcomes in the short and long term. Renal outcomes are being described and need to be pushed into later childhood and young adulthood; registries and pooled data will be required to gather this valuable information. Differences in needs for neonatal and childhood urologic surgical intervention need to be examined as do continence outcomes. Health status, functional status, and quality of life will be important components of coordinated followup. A well-rounded picture of the lives of children who do and do not receive fetal intervention is required to fully support care teams and families in informed decisionmaking at a supremely difficult time in which decisions require some degree of dispatch.

## State of the Science: Sacrococcygeal Teratoma

Background. Sacrococcygeal teratoma (SCT) is a relatively rare condition affecting approximately 1 in 40,000 fetuses or about 100 infants a year in the United States. As a result of ultrasound use, these tumors are increasingly recognized antenatally. The outcomes of prenatally diagnosed, uncomplicated survivors to term are generally good. However, those fetuses with large, vascular tumors have a high incidence of prenatal mortality from high-output cardiac failure or spontaneous hemorrhage into or rupture of the growing tumor. Fetal surgical procedures for SCT have focused on the small subgroup of fetuses with SCT and hydrops because untreated cases are expected to die in utero or at birth. All series report 100 percent mortality.103–109 In severe cases, SCT with hydrops is associated with maternal risks. Mothers of fetuses with hydrops can develop mirror syndrome, which is a severe form of preeclampsia and can be associated with placentomegaly. Mirror syndrome is a maternal contraindication to fetal approaches since the mother is critically ill and delivery has been felt to be indicated for maternal health. Consequently, decisions to intervene need to be made when the fetus is documented to be critically ill while the mother is still in good health.

Included publications. We identified seven publications107–108,110–114 that included fetal surgical procedures from five distinct populations of pregnancies affected by SCT. Procedures were associated with three fetal surgery groups based in an academic medical center. Two programs are in the United States, the other in the United Kingdom. Because this report is focused on surgical interventions, we have not included descriptions of percutaneous decompression of the SCT115 without shunt placement or other concomitant fetal intervention. Randomized clinical trials and prospective cohorts have not been reported. Four retrospective cohorts and one case series (Table 11) have examined varied maternal-fetal interventions, including 10 cases of open fetal surgery,110,112 11 cases of radiofrequency ablation,110,114 4 of laser vessel ablation,113 and 3 of alcohol sclerosis.113 Another publication reports in the broad category of “fetal intervention” for seven cases without specific details.108 In total, these studies include 130 fetuses with antenatal diagnosis of SCT, with 94 cases without fetal intervention or with only cyst aspiration. Overall, the expectant management cases are less severe (Table 12).

Table 11 Summary of studies of maternal-fetal surgical procedures for sacrococcygeal teratoma

Author Year | Open resection N | Other or no surgery N | Fetal inclusion criteria? | Maternal inclusion criteria? | Comparison group | Outcomes beyond neonatal hospital stay?
Randomized clinical trials and prospective cohorts
None
Retrospective cohorts
Grethel et al.110 2007 | 6 | 42 | Yes^*^ | No | RFA (7); no fetal procedure (35) | No
Danzer et al.111 2006 Hedrick et al.112 2004 | 4 | 26 | Yes | No | No fetal procedure | Yes (20–72 mos)
Makin et al.113 2006 | 0 | 29 | Yes | No | Varied interventions (8)^‡^;no fetal procedure (21) | Yes (8–86 mos)
Westerburg et al.108 2000 Schmidt et al.107 1989 | 7^*^ | 10 | Yes | No | No fetal procedure | No
Total | 17 | 109 | 4 of 4 | 0 of 4 | 4 of 4 | 2 of 4
Retrospective case series
Paek et al.114 2001 | 0 | 4 | Yes | No | No, all case RFA | Yes (12 mos)
Grand Total | 17 | 113 | 5 of 5 | 0 of 5 | 4 of 5 | 3 of 5

RFA = radiofrequency ablation;

* less detail for those without intervention;

‡ laser ablation, alcohol sclerosis, shunt placement for PUV

Table 12 Primary outcomes of maternal-fetal surgical procedures for sacrococcygeal teratoma

Author, Year, Country | Comparison groups, (N) | Key outcomes
Retrospective cohorts
Grethel et al.110 2007 U.S. | G1: open fetal procedure (6) G2: percutaneous radiofrequency ablation (7) G3: no fetal procedure (35) | - 2 of 6 with open surgery survived; all 4 deaths were among fetuses with hydrops; - 2 of 7 with RFA survived; 3 deaths were among fetuses with hydrops and 2 among those without hydrops; - Among those without fetal intervention and no hydrops there were five terminations and 16 of 17 remaining survived; - Among those without fetal intervention and hydrops there were four terminations and 1 survivor who was delivered preterm at 25 weeks at the onset of hydrops
Danzer et al.111 2006 Hedrick et al.112 2004 U.S. | G1: open fetal procedure (4) G2: no fetal surgery or cyst aspiration only (26) | - 3 of 4 fetuses survived open surgery (75%) and delivered between 27 and 31 weeks; - 4 of 26 fetal deaths with 4 additional terminations.; - 50% survived without intervention excluding terminations; - 90% of fetuses with other procedures, amnioreduction, amnioinfusion, and cyst aspiration, survived
Makin et al.113 2006 UK | G1: laser vessel ablation (4) G2: alcohol sclerosis (3) G3: vesicoamniotic shunt (1) G4: no fetal procedure (21) | - 1 of 4 with laser ablation survived; - 0 of 3 with alcohol sclerosis survived; - 1 of 1 shunt recipient survived; - 21 of 21 without fetal surgery for SCT survived ; 23 infants total survived to have definitive surgery including 2 of 8 with fetal surgery and 21 without; - Median followup of 39 months
Westerburg et al.108 2000 Schmidt et al.107 1989 U.S. | G1: “fetal intervention“ (7) G2: no fetal procedure (10) | - 3 of 7 with unspecified fetal intervention (43%) survived; all had hydrops; - 1 of 5 fetuses with hydrops and no intervention survived; infant was delivered at detection of hydrops at 32 weeks; - 2 of 5 with hydrops had pregnancy termination; - 5 of 5 without hydrops and no intervention survived; - Survival excluding terminations was 6 of 10 (60%)
Retrospective case series
Paek et al.114 2001 U.S. | G1: radiofrequency ablation (4) | - 2 of 4 survived to birth; - 2 deaths attributed to attempts to ablate larger portions of mass; - 2 survivors had ablation targeted to only major feeder vessels

RFA=radiofrequency ablation

Alcohol sclerosis was the least studied, and all three reported cases died. Radiofrequency ablation was also rarely reported; four of seven infants survived (Table 12). Of the five fetuses or infants that died after radiofrequency ablation, death was associated with hydrops in three cases, occurred in two infants without hydrops, and was associated with aggressive use of radiofrequency ablation to debulk tumor rather than ablate vessels only in two cases. The group that examined outcomes of radiofrequency ablation reports subsequent cases have only targeted major vessels, and both fetuses treated after this change survived.114 Laser vessel ablation in four cases with hydrops failed to salvage the fetuses and all died in utero or at birth.113

For open fetal procedures, the aggregate survival rates were 33 percent to 75 percent;110,112 both reported fetuses without hydrops survived in one group, and three of three without hydrops survived in the other. All fetal and neonatal deaths occurred among those with hydrops or with prodomal cardiovascular changes concerning for developing hydrops. In the comparison groups without fetal intervention or with only cyst aspiration to facilitate delivery, all cases with hydrops died, with the exception of two infants who were delivered promptly near the time that progression to hydrops was detected by frequent ultrasound surveillance. These infants were delivered at 25 and 32 weeks, respectively.108,110 Infants in both the intervention and no fetal intervention groups had complex hospital courses related to surgical intervention for the SCT. All who survived to surgery and who did not have fetal resection had surgery.

Long-term followup is limited; two groups provide only birth outcomes, and three provide longer term information out to 6 to 7 years of age.112–113 Chronic lung disease related to prematurity and recurrence of tumor has been sporadically reported in both fetal intervention and no fetal treatment groups. Of 22 surviving infants in all groups of the British cohort, the median hospital stay was 14 days and median followup is 39 months. Three cases were lost to followup after one year and were alive at that time; the remainder were known to be alive. One child had developmental delay, one had chronic constipation, and three needed cosmetic scar revision. None of the children, including six who were younger than 2 years of age, had other urologic or neurologic sequelae.113

All studies provided sufficient detail to understand the status of the infants included for procedures. Less information about antenatal course was available in some cases about the SCT cases that did not have interventions. One report included insufficient information about the nature of the procedures done. The latter paper was focused on predicting the occurrence of hydrops and thus presented limited intervention and outcome data. No studies characterized maternal inclusion criteria, though three did provide some information about maternal obstetrical complications and perioperative complications.

Summary of the SCT literature. Consistent with other newer fetal interventions, this literature will benefit over time from the anticipated transition to uniform, prospective data collection. Standardized classification systems and consistent assessment of similar case features will allow aggregation across sites and ultimately enough cases will be compiled to begin to stratify outcomes by risk group and to design the next generation of research to fully understand infant, childhood, and young adult outcomes including use of multivariable models and clinical trials. Other challenges for SCT include a need to focus on the optimal timing of fetal interventions and early and reliable detection of fetuses which will or are developing hydrops or cardiac decompensation. The overriding comment from key informants was related to the importance of very careful patient selection. SCTs do not necessarily need to be addressed in utero, and in the absence of incipient hydrops, treatment should be postponed until the postnatal period. The “right” patients for this procedure are extraordinarily rare—even the site with the greatest experience reports doing fewer than 10.

## State of the Science: Thoracic Lesions

Background. Congenital pulmonary airway malformations (CPAM), which include congenital cystic adenomatoid malformation (CCAM) and bronchopulmonary sequestration (BPS), are congenital anomalies of the lung that share the characteristic of a segment of lung being replaced by abnormally developing tissue. CCAMs can have connections to the pulmonary tree and contain air. The tissue is served by blood vessels in the pulmonary circulation.116 BPS does not connect to airway and has blood flow from branches off the aorta as well as the pulmonary circulation. Antenatal diagnosis is most often made by ultrasound.

Only a small subset of patients with congenital pulmonary airway malformations are candidates for in utero treatment. In this subset, the mass is large enough and in such an anatomically critical position that the fetal mediastinum is compressed, leading to impaired venous return with resulting fetal hydrops secondary to cardiac failure. When this occurs early enough in gestational age that delivery and postnatal treatment are not an option, in utero treatment is a possible solution. The majority of CPAMs, however, do not have an indication for prenatal treatment as the outcomes are excellent, with the tumors often regressing throughout pregnancy and causing no neonatal or early childhood symptoms.

Oftentimes the more difficult judgments to be made during pregnancy are the frequency with which these tumors should be monitored in order to detect the small percentage that will cause fetal harm in order to know when to intervene. Distinguishing between these conditions is difficult and some would argue clinically irrelevant until after birth. The final common pathway that leads to consideration of fetal intervention is the same—fetal hydrops—whether the lesion is considered a pure CCAM, BPS, or a hybrid lesion.

There are presently no useful predictors of outcome for thoracic lesions, and serial evaluations are essential to determine course. Hydrops in the fetus results from obstruction of the vena cava and cardiac compression caused by mediastinal shift.117 The decision to intervene in utero is often based on the natural history reports that hydrops marks a transition to fetal demise. At times large pleural effusions occur without CCAM or BPS; the natural history of these effusions is even less well understood. We did not include interventions for isolated pleural effusions in this review; neither did we include papers that only reported thoracocentesis as a treatment.

Included publications. No randomized trials have focused on maternal-fetal intervention for CCAMS or BPS (Table 13). Our search identified 17 publications in which the authors focused on lesions thought antenatally to be CCAMs or in which the anomalies were simply classified as thoracic or pulmonary masses. They included: 13 publications about 6 distinct cohorts,24,110,117–127 and 4 case series reports88,98,128–129 about 3 distinct study populations from a total of 7 academic groups in the United States, South America, Europe, and Japan. Collectively, their participants represent approximately 401 fetuses believed to have CCAMs, of which 54 had thoracoamniotic shunting and 3 had open procedures, with the goal of decompressing the lung lesion. Two retrospective cohorts focused on a total of 13 fetuses with bronchopulmonary sequestration.120,130 Fetal intervention for both CCAMs and BPS are summarized in Table 14.

The total literature available included 88 infants with untreated hydrops associated with CCAM. Of these infants, five survived (5.7 percent); four of these improved after a course of steroids. The intervention literature suggests a 54 percent overall survival to birth after maternal-fetal intervention, with survival as low as 20 percent to 33 percent among fetuses with hydrops.110,120 In cohorts, 44 percent to 100 percent of infants who had thoracoamniotic shunts placed survived to birth or through neonatal hospitalization.110,118,126–128

A team treating 13 fetuses with open fetal surgery achieved 61 percent survival through seven years of followup, with normal neurodevelopmental followup for the 4 infants with formal evaluation up to 47 months of age. In the same group of patients from this surgical group, all infants without hydrops survived, and 66 of 76 (87 percent) required postnatal resection.24,117,120–124 This is similar to 56 percent survival reported for open surgery by another team who operated on 25 fetuses, of which 23 had hydrops.110 Another group reported intraoperative death or fetal demise in three cases of open fetal surgery in the setting of hydrops.127 Uniform survival of infants without hydrops has been reported by several groups.118–119,125–127

Among fetuses with shunts for BPS three of three survived; however, as for CCAMs, a number of fetuses, in one series 67 percent, have spontaneous regression of the lesion in utero or after birth and do not require resection. The proportion of infants requiring surgery for resection of the lesions may not be reduced by fetal intervention. Outcomes beyond survival have been examined in only a few series. Merchant and colleagues125 reported chest wall and rib deformities in two of nine patients treated with fetal shunts. Gibbs and colleagues24 reported on neurologic outcomes of 11 infants with open fetal surgery for all types of lesions; 9 were developing normally.

Fetal inclusion criteria or detailed case descriptions are included in each of the identified publications; reporting of anesthesia approach is also well described. Subsequent surgical intervention in both those infants treated as fetuses and after birth is nearly complete. However, information about factors related to maternal selection and complications is meager. Length of followup is highly variable, with infants followed up past the newborn hospital stay in 7 of 16 publications; 4 provided any neurologic outcomes in infancy or childhood; and none provide formal evaluation of pulmonary function in childhood.

Summary of thoracic lesions literature. The literature on congenital lung lesions is dominated by reports of isolated or repeated use of thoracocentesis, which was not a maternal-fetal surgical intervention directly addressed by this report. This smaller body of literature about open maternal-fetal surgeries and thoracoamniotic shunt placement reflects a wide range of differences in spectrum of fetuses treated. Over time, interest has evolved in the direction of treating only those infants with poor prognosis as indicated by fetal hydrops. While logical, this creates lack of comparability of infants who received and did not receive fetal treatment. Other aspects of changes in contemporary care may also be influencing how cohorts and case series are interpreted. Recent advances in the CCAM literature include the report of three cases of a novel therapy involving percutaneous fetal sclerotherapy in 2008.^131^ Additionally, some infants with large CCAMs may respond to in utero medical treatment with steroids.110,127 Combined, the two teams have reported seven infants with CCAM and hydrops, with resolution of the lesion in all seven. Currently a multicenter trial is being organized at the University of California, San Francisco, the Fetal Care Center of Cincinnati, and the Children’s Hospital of Philadelphia, which will randomize select infants with CCAM to steroid or no steroid treatment. Future interventions may also have failure to respond to steroids as an entry criterion.

## State of the Science: Twin-Twin Transfusion Syndrome

Background. In twin-to-twin transfusion syndrome (TTTS), twins share a single chorionic membrane and therefore a single placenta, but have separate amniotic sacs. Approximately 15 percent of monochorionic, diamniotic twin pregnancies are affected by TTTS,132 and therefore, estimates based on CDC data are that theoretical incidence of TTTS would be about 1.38 to 1.86 cases per 1,000 live births.133 Although incidence studies have found lower numbers, these numbers are probably a reflection of early deaths of affected fetuses in utero that therefore do not get recognized as TTTS pregnancies.

Most pregnancies presenting with severe TTTS prior to 26 weeks and not undergoing some sort of therapy will end with dual fetal demise.132 When both twins do survive, there is often severe neurologic compromise in survivors as well as other organ failure, including cardiac conditions. Approximately 25 percent of surviving fetuses in a monochorionic twin pair in which one dies will suffer CNS injury.

Diagnostic criteria for TTTS have evolved to include: same-sex fetuses with a single placenta with lack of lambda sign in early pregnancy; oligohydramnios in the donor sac (<2 cm maximum vertical pocket); and polyhydramnios in the recipient sac (>8 cm maximum vertical pocket at less than 20 weeks or >10 cm after 20 weeks).

After diagnosis, the most common approach to assessing severity in TTTS is the Quintero staging system:134

- Stage I: The fetal bladder of the donor twin remains visible sonographically.
- Stage II: The bladder of the donor twin is collapsed and not visible by ultrasound.
- Stage III: Critically abnormal fetal Doppler studies noted. This may include absent or reversed end-diastolic velocity in the umbilical artery, absent or reverse flow in the ductus venosus, or pulsatile flow in the umbilical vein.
- Stage IV: Fetal hydrops present.
- Stage V: Demise of one or both twins.

In 1990, Baldwin and Wittman135 presented three prenatally diagnosed twin pairs with in utero TTTS for which they attempted selective reduction. They postulated the importance of a vascular separation. Later that year, De Lia et al reported the first fetal surgery to treat the underlying pathology.136

Four primary approaches exist for intervening in TTTW:

- Serial amnioreduction to relieve intra-amniotic pressure and uterine size, and thus prolong the pregnancy. Although the mechanism by which it works is not entirely clear, amnioreduction has been associated with a 50–60 percent survival rate of at least one fetus.137
- Termination of the sicker twin, which is likely to rescue the healthier one and is accomplished by cord occlusion, radio frequency ablation, or ligation. This is only used in the presence of significant birth defects.
- Septostomy, in which the intervening membranes is punctured to attempt to increase amniotic fluid in the oligohydramniotic sac, was performed but has largely been abandoned as a therapy.138
- Laser ablation of communicating vessels is performed either selectively or non-selectively to attempt to protect one twin from hemodynamic disturbances in the other twin. In nonselective ablation, all vessels crossing the dividing membrane are ablated, whereas selective ablation is limited to vessels shown to be communicating between the two fetuses. Selective ablation is most common today, and is the focus of this section of the technical brief. Gaining access to the uterus can be accomplished in three ways: laparotomy to expose the uterus, laparoscopic placement of the fetoscope, and ultrasound-guided placement of the fetoscope.

Included publications. We searched specifically for literature on laser treatment for TTTS; therefore, we defined cohort studies as those that included comparisons either of types of laser to other types of treatment or to no treatment. Studies in which all participants received laser treatment were considered case series even if the data were presented for separate groups, such as by severity.

The treatment literature evaluating laser ablation for TTTS included 2 RCTs,139–140 3 prospective cohorts,141,143–144 7 retrospective cohorts142,145–152 and 73 case series (Table 15). Although we attempted to group “families” of publications in which specific pregnancies may be reported in duplicate, we were unable to do so definitively, and there is likely substantial overlap among the populations in the studies. Our best estimate is that approximately 1,790 pregnancies treated with laser ablation for TTTS have been reported in the literature. Of the 77 papers, 42 specified using selective laser ablation and 14 nonselective, including 3 that reported using both (sometimes in direct comparison). Of 54 studies reporting the type of anesthesia used, 15 used general, 26 used local and 13 used epidural.

Table 15 Summary of trials and cohort studies of laser ablation for twin-twin transfusion syndrome (TTTS)

Author Year | With laser ablation N | Without laser or other procedure N | Fetal inclusion criteria? | Maternal inclusion criteria? | Comparison group | Outcomes beyond neonatal hospital stay?
Randomized controlled trials
Crombleholme et al.139 2007 | 20 | 20 | Yes | No | Amnioreduction | Yes (30 days postnatal)
Senat et al.140 2004 | 72 | 70 | Yes | No | Amnioreduction | Yes (7–12 mos)
Total | 92 | 90 | 2 of 2 | 0 of 2 | 2 of 2 | 2 of 2
Prospective cohorts
Chmait et al.141–142 2010 | 99 | -- | Yes | No | Sequential vs. nonsequential laser ablation | No
Quintero et al.143 2007 | 193 | --^*^ | Yes | No | Sequential vs. nonsequential laser ablation | No
Gardiner et al.144 2003 | 13 | 14 | Yes | No | Symptomatic management | Yes (mean 11.1 mos)
Total | 305 | 14 | 3 of 3 | 3 of 3 | 2 of 3 | 1 of 3
Retrospective cohorts
Habli et al.145 2008 | 26 | 26 | Yes | No | Amnioreduction (15), radio-frequency ablation (4), no fetal surgery (7) | No
Lenclen et al.146–147 2007 | 101 | 36 | Yes | No | Amnioreduction | No
Middeldorp et al.148–149 2007 | 20 | 30 | Yes | No | Conservative management | Yes
Santiago et al.150 2006 | 16 | -- | No | No | Prior amnioreduction | No
Quintero et al.151 2003 | 95 | 78 | Yes | No | Amnioreduction | No
Quintero et al.152 2000 | 92 | -- | Yes | No | Selective vs. nonselective | No
Total | 345 | 160 | 5 of 6 | 0 of 6 | 6 of 6 | 1 of 6

* These cohorts reflect differences in laser ablation approach (e.g. selective vs. nonselective) or prior intervention (e.g. with or without prior amnioreduction) as the basis for comparisons across groups.

Until 2000, all publications were case series, with the first RCT reported in 2004. The vast majority of studies (including all of the newer ones) that report surgical approach indicate that they used a percutaneous approach with a fetoscope. All but one of the reports using laparotomy to gain access to the uterus were by the same group, early in the series. This may reflect advances in instrumentation which improved minimally invasive access surgery during this time. Some laparotomy cases were done to gain access to an anteriorly placed placenta without transplacental fetoscope placement.

Both RCTs139–140 used amnioreduction as their comparison group. One required that pregnancies first have an amnioreduction prior to randomization139 The other excluded patients with prior invasive treatment.140 Only pregnancies in which initial amnioreduction was non-therapeutic were enrolled in the study. Both studies were stopped before completion under standard stopping rules at planned interim analyses. The earlier study140 had a higher rate of survival at 7 to 12 months of age of at least one twin in the laser group relative to the amnioreduction group (p=.002). Although survival rates were higher among lower Quintero-staged pregnancies in general, there was still greater survival among higher Quintero-staged pregnancies in the laser group. Cerebral lesions were also significantly less likely in the laser group compared to amnioreduction (7 percent of survivors in laser versus 35 percent of survivors in AR; p=.02).

In the Crombleholme study, there was a statistically significant increase in fetal mortality among recipient twins treated with laser (63 percent) versus amnioreduction (12.5 percent), but no difference in survival at 30 days. There was also no difference in survival among donor twins. Small numbers, however, make these results difficult to assess.

Nonetheless, the studies cannot be directly compared: the Senat study, which had more positive outcomes for laser intervention included women with any Quintero stage TTTS, whereas the Crombleholme study excluded women with stage 1 TTTS, thus focusing on a more severely impaired group. The Senat study also included pregnancies up to gestational ages of 26 weeks, compared to an upper limit of 22 weeks in the Crombleholme study.

Of the nine cohort studies, three were prospective and six were retrospective. Five included data that allowed comparisons of amnioreduction to laser ablation.144–146,148,151 Two compared selective to nonselective approaches,143,152 and one considered whether having had a prior amnioreduction conferred risk of worse outcomes on pregnancies undergoing laser ablation.150

The five studies that included data allowing for a comparison between amnioreduction and laser showed mixed results (Table 16), but because these studies were all nonrandomized, this could very well reflect unmeasured differences in study populations or differences in laser technique or experience. In one of the two studies that did not demonstrate a survival benefit for laser relative to AR,148 however, substantially higher morbidity was observed among the neonates who had been treated with AR. One study147 followed a subset of twins from another retrospective cohort146 and found similar neurodevelopmental outcomes in survivors treated with laser as seen in a group of dichorionic twins. Survivors of amnioreduction had increased neurodevelopmental delay at 2 years, as measured by the Ages and Stages questionnaire.

Table 16 Primary outcomes of trials and cohort studies of laser ablation for TTTS

Author, Year, Country | Comparison groups, (N) | Key outcomes
Chavira et al.142 2009 U.S. | G1: very short cervical length, 0.5–1.9 cm (10) G2: moderate cervical length, 2–2.5 cm (13) G3: normal cervical length, >2.5 cm (76) | - 3/10 patients in the very short cervical length group had prior AR and 8/10 underwent cerclage; - No significant differences among groups in gestational age at delivery, 30-day neonatal survival, or latency from time of surgery to delivery; - Overall at least 1 neonatal survivor in 90 of 99 cases (91%), dual survival in 71/99 cases (72%)
Habli et al.145 2008 U.S. | G1: SFLP (26) G2: AR (15) G3: RFA (4), G4: expectant management (7) | - No significant difference in donor or recipient survival rate (p=0.058) or gestational age at delivery among treatment groups (p=.5)
Crombleholme et al.139 2007 U.S. | G1: SFLP (20) G2: AR (20) | - No significant difference in 30-day postnatal survival between donors or recipients by group; - No difference in 30-day survival of one or both twins on a per-pregnancy basis; - Significant increase in fetal recipient mortality in the SFLP arm, offset by increased recipient neonatal mortality in the AR arm; - Echocardiographic abnormality in recipient twin; CVPS most significant (p=0.055) predictor of recipient mortality by logistic regression
Lenclen et al.146–147 2007 France | G1: laser ablation (101) G2: amnioreduction (36) G3: unattended dichorionic twins delivered at 24–34 weeks of gestation (242) | - Death or severe cerebral lesions more frequent in the amnioreduction group than laser or dichorionic groups; - No significant difference in overall neonatal outcome between laser and normal dichorionic neonates; - Neonatal morbidity higher in laser neonates delivered at <30 weeks’ gestation when due to failed laser therapy; - Neurodevelopmental delays greater at 2 years in G2 compared with the other 2 groups
Middeldorp et al.148–149 2007 Netherlands | G1: laser surgery, presenting after 26 weeks of gestation (10) G2: conservative management (30) | - No significant difference was found between groups in the median gestational age at birth; - Long term neurodevelopmental delay in 0% of G1 vs. 23% of G2 (p=.03); - Major neonatal morbidity occurred more often in the amniodrainage group (26%) than laser surgery group (7%), (p=0.04); - No significant difference in rates of severe cerebral injury (p=1.00), neonatal mortality (p=0.54), or overall adverse outcome (p=0.83) between groups
Quintero et al.143 2007 U.S. | G1: selective laser photocoagulation of communicating vessels (SLPCV) (56) G2: sequential SLPCV (137) | - Pregnancies in which sequential SLPCV (G2) was done were more likely (p=.02) to have 2 surviving fetuses (73% vs. 57%); - Differences for at least one surviving fetus were non-significant
Santiago et al.150 2006 Spain | G1: laser without prior AR (10) G2: laser with prior AR (6) | - No substantial differences in survival rates between the groups, but the sample size was small
Senat et al.140 2004 France, Belgium, Switzerland | G1: selective laser SFLP therapy (72) G2: amnioreduction (70) | - Neonatal survival greater in G1 vs. G2 (p=0.0009); - Survival to 6 months of age was greater in G1 vs. G2 (p=0.002); - Incidence of cystic periventricular leukomalacia was lower in G1 vs. G2 at 6 months (p=0.003)
Gardiner et al.144 2003 UK, Germany | G1: TTTS treated symptomatically (14) G2: laser ablation (13) G3: pregnancies w/monochorionic twins w/o TTTS (12) G4: normal dichorionic twins (11) | - Gestational age and birthweight slightly greater in G2 than G1 but no assessment of statistical significance for comparison; - No significant differences in blood pressure or intrauterine growth between G1 and G2
Quintero et al.151 2003 U.S., Australia | G1: SFLP (95) G2: serial amnioreduction (173) | - Likelihood of at least one surviving infant was correlated inversely with stage in G2 but not G1; - G1 was 2.4 times more likely to have at least one survivor than G2; - Neurologic morbidity related to stage in G2 but not G1; - Neurologic morbidity significantly higher in G2 vs. G1
Quintero et al.152 2000 U.S. | G1: SFLP G2: nonselective laser | - Higher survival of at least one fetus in selective (83%) vs. nonselective (61%) (p=0.04)

AR=amnioreduction; CVPS=cardiovascular profile score; RFA=radiofrequency ablation; SFLP=selective laser photocoagulation; SLPCV= selective laser photocoagulation of communicating vessels; TTTS=Twin-twin transfusion syndrome

Two studies by the same group examined modifications to the general technique: selective versus nonselective152 and sequential versus nonsequential approaches.143 Both selective and sequential approaches were associated with greater survival rates. In a retrospective comparison of 16 patients referred for laser, some of whom had a prior amnioreduction, there was no difference between patients who had or had not had prior AR. Finally, one prospective cohort142 found no difference in outcomes of laser treatment by cervical length at admission.

The many case series available in this literature are helpful in surveying the range of success rates and in identifying potential harms associated with treatment.153 Preterm premature rupture of membranes is the most commonly noted short-term harm, with a range of 4 percent154 to 28 percent.155 Longer term developmental outcomes in the infants have been examined in a small number of studies, and although a high rate of neurodevelopmental impairment is noted,156 none of these studies included a treatment comparison group, so the relative benefit or harm of laser treatment on these outcomes is unknown.

Experts in treatment for TTTS stressed the importance of very stringent techniques, particularly in mapping the vessels and incorporating checks and balances into the process; mapping techniques and the need for stringent processes, however, are not well evaluated in the literature and likely warrant further study. Two key informants spoke to their concerns that complications are substantially higher outside of the larger centers, but without a system for documenting outcomes and outside of the research enterprise, actual rates cannot be captured.

Summary of the TTTS literature. Case series comprise the bulk of TTTS literature discussed in this review. Two RCTs meeting our criteria compared amnioreduction to laser ablation; similarly, five of the eight cohort studies reported here compared laser ablation and amnioreduction. Consensus about the superiority of vascular ablation procedures versus amnioreduction is developing, but as in other fetal procedures, small sample sizes and differences between study groups limit comparisons. The TTTS literature also lacks substantial long-term fetal and maternal outcomes data.