# References and Included Studies

1 Ashburn DA, Blackstone EH, Wells WJ, et al. Determinants of mortality and type of repair in neonates with pulmonary atresia and intact ventricular septum. J Thorac Cardiovasc Surg. 04. 2004;127(4):1000-1007. discussion 1007–1008. [pmid: 15052196].
2 Shinebourne EA, Rigby ML, Carvalho JS. Pulmonary atresia with intact ventricular septum: from fetus to adult: congenital heart disease. Heart. 10. 2008;94(10):1350-1357. [pmid: 18801793].
3 Tulzer G, Arzt W, Franklin RC, et al. Fetal pulmonary valvuloplasty for critical pulmonary stenosis or atresia with intact septum. Lancet. 11. 16. 2002;360(9345):1567-1568. [pmid: 12443597].
4 Mizrahi-Arnaud A, Tworetzky W, Bulich LA, et al. Pathophysiology, management, and outcomes of fetal hemodynamic instability during prenatal cardiac intervention. Pediatr Res. 09. 2007;62(3):325-330. [pmid: 17622948].
5 McElhinney DB, Marshall AC, Wilkins-Haug LE, et al. Predictors of technical success and postnatal biventricular outcome after in utero aortic valvuloplasty for aortic stenosis with evolving hypoplastic left heart syndrome. Circulation. 10. 13. 2009;120(15):1482-1490. [pmid: 19786635].
6 McElhinney DB, Benson CB, Brown DW, et al. Cerebral blood flow characteristics and biometry in fetuses undergoing prenatal intervention for aortic stenosis with evolving hypoplastic left heart syndrome. Ultrasound Med Biol. 01. 2010;36(1):29-37. [pmid: 19931971].
7 Wilkins-Haug LE, Tworetzky W, Benson CB, et al. Factors affecting technical success of fetal aortic valve dilation. Ultrasound Obstet Gynecol. 07. 2006;28(1):47-52. [pmid: 16795115].
8 Marshall AC, Tworetzky W, Bergersen L, et al. Aortic valvuloplasty in the fetus: technical characteristics of successful balloon dilation. J Pediatr. 10. 2005;147(4):535-539. [pmid: 16227042].
9 Tworetzky W, Wilkins-Haug L, Jennings RW, et al. Balloon dilation of severe aortic stenosis in the fetus: potential for prevention of hypoplastic left heart syndrome: candidate selection, technique, and results of successful intervention. Circulation. 10. 12. 2004;110(15):2125-2131. [pmid: 15466631].
10 Kohl T, Sharland G, Allan LD, et al. World experience of percutaneous ultrasound-guided balloon valvuloplasty in human fetuses with severe aortic valve obstruction. Am J Cardiol. 05. 15. 2000;85(10):1230-1233. [pmid: 10802006].
11 Maxwell D, Allan L, Tynan MJ. Balloon dilatation of the aortic valve in the fetus: a report of two cases. Br Heart J. 05. 1991;65(5):256-258. [pmid: 2039669].
12 Marshall AC, van der Velde ME, Tworetzky W, et al. Creation of an atrial septal defect in utero for fetuses with hypoplastic left heart syndrome and intact or highly restrictive atrial septum. Circulation. 07. 20. 2004;110(3):253-258. [pmid: 15226215].
13 Marshall AC, Levine J, Morash D, et al. Results of in utero atrial septoplasty in fetuses with hypoplastic left heart syndrome. Prenat Diagn. 11. 2008;28(11):1023-1028. [pmid: 18925607].
14 Allan LD, Maxwell DJ, Carminati M, et al. Survival after fetal aortic balloon valvoplasty. Ultrasound Obstet Gynecol. 02. 1995;5(2):90-91. [pmid: 7719873].
15 Hospital stays, hospital charges, and inhospital deaths among infants with selected birth defects—United States, 2003. MMWR Morb Mortal Wkly Rep. 01. 19. 2007;56(2):25-29. [pmid: 17230142].
16 National Center on Birth Defects and Developmental Disabilities. Metropolitan Atlanta Congenital Defects Program 2004 Annual Report. Atlanta, GA. Centers for Disease Control and Prevention. 2004.
17 Quintero RA, Huhta J, Suh E, et al. In utero cardiac fetal surgery: laser atrial septotomy in the treatment of hypoplastic left heart syndrome with intact atrial septum. Am J Obstet Gynecol. 10. 2005;193(4):1424-1428. [pmid: 16202736].
18 Glatz JA, Tabbutt S, Gaynor JW, et al. Hypoplastic left heart syndrome with atrial level restriction in the era of prenatal diagnosis. Ann Thorac Surg. 11. 2007;84(5):1633-1638. [pmid: 17954074].
19 Rudolph CD, Rudolph AM, Hostetter MK, et al., editors. Rudolph’s pediatrics. New York. McGraw-Hill Medical Pub Div. 2003.
20 Butler N, Claireaux AE. Congenital diaphragmatic hernia as a cause of perinatal mortality. Lancet. 03. 31. 1962;1(7231):659-663. [pmid: 13875198].
21 Cortes RA, Keller RL, Townsend T, et al. Survival of severe congenital diaphragmatic hernia has morbid consequences. J Pediatr Surg. 01. 2005;40(1):36-45. discussion 45–46. [pmid: 15868556].
22 Deprest J, Gratacos E, Nicolaides KH. Fetoscopic tracheal occlusion (FETO) for severe congenital diaphragmatic hernia: evolution of a technique and preliminary results. Ultrasound Obstet Gynecol. 08. 2004;24(2):121-126. [pmid: 15287047].
23 Flake AW, Crombleholme TM, Johnson MP, et al. Treatment of severe congenital diaphragmatic hernia by fetal tracheal occlusion: clinical experience with fifteen cases. Am J Obstet Gynecol. 11. 2000;183(5):1059-1066. [pmid: 11084541].
24 Gibbs DL, Piecuch RE, Graf JL, et al. Neurodevelopmental outcome after open fetal surgery. J Pediatr Surg. 08. 1998;33(8):1254-1256. [pmid: 9721998].
25 Harrison MR, Adzick NS, Bullard KM, et al. Correction of congenital diaphragmatic hernia in utero VII: a prospective trial. J Pediatr Surg. 11. 1997;32(11):1637-1642. [pmid: 9396545].
26 Harrison MR, Adzick NS, Flake AW, et al. Correction of congenital diaphragmatic hernia in utero: VI. Hard-earned lessons. J Pediatr Surg. 10. 1993;28(10):1411-1417. discussion 1417–1418. [pmid: 8263712].
27 Harrison MR, Adzick NS, Flake AW, et al. Correction of congenital diaphragmatic hernia in utero VIII: Response of the hypoplastic lung to tracheal occlusion. J Pediatr Surg. 10. 1996;31(10):1339-1348. [pmid: 8906657].
28 Harrison MR, Albanese CT, Hawgood SB, et al. Fetoscopic temporary tracheal occlusion by means of detachable balloon for congenital diaphragmatic hernia. Am J Obstet Gynecol. 09. 2001;185(3):730-733. [pmid: 11568805].
29 Harrison MR, Keller RL, Hawgood SB, et al. A randomized trial of fetal endoscopic tracheal occlusion for severe fetal congenital diaphragmatic hernia. N Engl J Med. 11. 13. 2003;349(20):1916-1924. [pmid: 14614166].
30 Harrison MR, Langer JC, Adzick NS, et al. Correction of congenital diaphragmatic hernia in utero, V. Initial clinical experience. J Pediatr Surg. 01. 1990;25(1):47-55. discussion 56–57. [pmid: 2405147].
31 Harrison MR, Mychaliska GB, Albanese CT, et al. Correction of congenital diaphragmatic hernia in utero IX: fetuses with poor prognosis (liver herniation and low lung-to-head ratio) can be saved by fetoscopic temporary tracheal occlusion. J Pediatr Surg. 07. 1998;33(7):1017-1022. discussion 1022–1023. [pmid: 9694087].
32 Harrison MR, Sydorak RM, Farrell JA, et al. Fetoscopic temporary tracheal occlusion for congenital diaphragmatic hernia: prelude to a randomized, controlled trial. J Pediatr Surg. 07. 2003;38(7):1012-1020. [pmid: 12861529].
33 Heerema AE, Rabban JT, Sydorak RM, et al. Lung pathology in patients with congenital diaphragmatic hernia treated with fetal surgical intervention, including tracheal occlusion. Pediatr Dev Pathol. 11-12. 2003;6(6):536-546. [pmid: 15018453].
34 Hubbard AM, Adzick NS, Crombleholme TM, et al. Left-sided congenital diaphragmatic hernia: value of prenatal MR imaging in preparation for fetal surgery. Radiology. 06. 1997;203(3):636-640. [pmid: 9169681].
35 Jani J, Gratacos E, Greenough A, et al. Percutaneous fetal endoscopic tracheal occlusion (FETO) for severe left-sided congenital diaphragmatic hernia. Clin Obstet Gynecol. 12. 2005;48(4):910-922. [pmid: 16286838].
36 Jani JC, Nicolaides KH, Gratacos E, et al. Fetal lung-to-head ratio in the prediction of survival in severe left-sided diaphragmatic hernia treated by fetal endoscopic tracheal occlusion (FETO). Am J Obstet Gynecol. 12. 2006;195(6):1646-1650. [pmid: 16769018].
37 Keller RL, Glidden DV, Paek BW, et al. The lung-to-head ratio and fetoscopic temporary tracheal occlusion: prediction of survival in severe left congenital diaphragmatic hernia. Ultrasound Obstet Gynecol. 03. 2003;21(3):244-249. [pmid: 12666218].
38 Keller RL, Hawgood S, Neuhaus JM, et al. Infant pulmonary function in a randomized trial of fetal tracheal occlusion for severe congenital diaphragmatic hernia. Pediatr Res. 11. 2004;56(5):818-825. [pmid: 15319458].
39 Kohl T, Gembruch U, Filsinger B, et al. Encouraging early clinical experience with deliberately delayed temporary fetoscopic tracheal occlusion for the prenatal treatment of life-threatening right and left congenital diaphragmatic hernias. Fetal Diagn Ther. 2006;21(3):314-318. [pmid: 16601345].
40 Peralta CF, Jani JC, Van Schoubroeck D, et al. Fetal lung volume after endoscopic tracheal occlusion in the prediction of postnatal outcome. Am J Obstet Gynecol. 01. 2008;198(1):60e1-60e5. [pmid: 17826727].
41 Saura L, Castanon M, Prat J, et al. Impact of fetal intervention on postnatal management of congenital diaphragmatic hernia. Eur J Pediatr Surg. 12. 2007;17(6):404-407. [pmid: 18072025].
42 Danzer E, Davey MG, Kreiger PA, et al. Fetal tracheal occlusion for severe congenital diaphragmatic hernia in humans: a morphometric study of lung parenchyma and muscularization of pulmonary arterioles. J Pediatr Surg. 10. 2008;43(10):1767-1775. [pmid: 18926205].
43 Sinha CK, Islam S, Patel S, et al. Congenital diaphragmatic hernia: prognostic indices in the fetal endoluminal tracheal occlusion era. J Pediatr Surg. 02. 2009;44(2):312-316. [pmid: 19231524].
44 Peiro JL, Carreras E, Guillen G, et al. Therapeutic indications of fetoscopy: a 5-year institutional experience. J Laparoendosc Adv Surg Tech A. 04. 2009;19(2):229-236. [pmid: 19260783].
45 Cannie MM, Jani JC, De Keyzer F, et al. Evidence and patterns in lung response after fetal tracheal occlusion: clinical controlled study. Radiology. 08. 2009;252(2):526-533. [pmid: 19508989].
46 Jani J, Keller RL, Benachi A, et al. Prenatal prediction of survival in isolated left-sided diaphragmatic hernia. Ultrasound Obstet Gynecol. 01. 2006;27(1):18-22. [pmid: 16374756].
47 Mathews TJ, Honein MA, Erickson JD. Spina bifida and anencephaly prevalence—United States, 1991–2001. MMWR Recomm Rep. 09. 13. 2002;51(RR-13):9-11. [pmid: 12353510].
48 Tubbs RS, Chambers MR, Smyth MD, et al. Late gestational intrauterine myelomeningocele repair does not improve lower extremity function. Pediatr Neurosurg. 03. 2003;38(3):128-132. [pmid: 12601237].
49 Tulipan N, Bruner JP, Hernanz-Schulman M, et al. Effect of intrauterine myelomeningocele repair on central nervous system structure and function. Pediatr Neurosurg. 10. 1999;31(4):183-188. [pmid: 10705927].
50 Bruner JP, Tulipan N, Paschall RL, et al. Fetal surgery for myelomeningocele and the incidence of shunt-dependent hydrocephalus. JAMA. 11. 17. 1999;282(19):1819-1825. [pmid: 10573272].
51 Danzer E, Johnson MP, Bebbington M, et al. Fetal head biometry assessed by fetal magnetic resonance imaging following in utero myelomeningocele repair. Fetal Diagn Ther. 2007;22(1):1-6. [pmid: 17003546].
52 Adelberg A, Blotzer A, Koch G, et al. Impact of maternal-fetal surgery for myelomeningocele on the progression of ventriculomegaly in utero. Am J Obstet Gynecol. 09. 2005;193(3 Pt 1):727-731. [pmid: 16150266].
53 Hamdan AH, Walsh W, Bruner JP, et al. Intrauterine myelomeningocele repair: effect on short-term complications of prematurity. Fetal Diagn Ther. 01-02. 2004;19(1):83-86. [pmid: 14646425].
54 Tulipan N, Sutton LN, Bruner JP, et al. The effect of intrauterine myelomeningocele repair on the incidence of shunt-dependent hydrocephalus. Pediatr Neurosurg. 01. 2003;38(1):27-33. [pmid: 12476024].
55 Bruner JP, Tulipan NB, Richards WO, et al. In utero repair of myelomeningocele: a comparison of endoscopy and hysterotomy. Fetal Diagn Ther. 03-04. 2000;15(2):83-88. [pmid: 10720871].
56 Johnson MP, Sutton LN, Rintoul N, et al. Fetal myelomeningocele repair: short-term clinical outcomes. Am J Obstet Gynecol. 08. 2003;189(2):482-487. [pmid: 14520222].
57 Johnson MP, Gerdes M, Rintoul N, et al. Maternal-fetal surgery for myelomeningocele: neurodevelopmental outcomes at 2 years of age. Am J Obstet Gynecol. 04. 2006;194(4):1145-1150. discussion 1150–1152. [pmid: 16580316].
58 Koh CJ, DeFilippo RE, Borer JG, et al. Bladder and external urethral sphincter function after prenatal closure of myelomeningocele. J Urol. 11. 2006;176(5):2232-2236. [pmid: 17070301].
59 Danzer E, Johnson MP, Wilson RD, et al. Fetal head biometry following in-utero repair of myelomeningocele. Ultrasound Obstet Gynecol. 11. 2004;24(6):606-611. [pmid: 15517548].
60 Wilson RD, Johnson MP, Bebbington M, et al. Does a myelomeningocele sac compared to no sac result in decreased postnatal leg function following maternal fetal surgery for spina bifida aperta?. Fetal Diagn Ther. 2007;22(5):348-351. [pmid: 17556822].
61 Mazzola CA, Albright AL, Sutton LN, et al. Dermoid inclusion cysts and early spinal cord tethering after fetal surgery for myelomeningocele. N Engl J Med. 07. 25. 2002;347(4):256-259. [pmid: 12140301].
62 Sutton LN, Adzick NS, Bilaniuk LT, et al. Improvement in hindbrain herniation demonstrated by serial fetal magnetic resonance imaging following fetal surgery for myelomeningocele. JAMA. 11. 17. 1999;282(19):1826-1831. [pmid: 10573273].
63 Danzer E, Adzick NS, Rintoul NE, et al. Intradural inclusion cysts following in utero closure of myelomeningocele: clinical implications and follow-up findings. J Neurosurg Pediatr. 12. 2008;2(6):406-413. [pmid: 19035686].
64 Danzer E, Finkel RS, Rintoul NE, et al. Reversal of hindbrain herniation after maternal-fetal surgery for myelomeningocele subsequently impacts on brain stem function. Neuropediatrics. 12. 2008;39(6):359-362. [pmid: 19569004].
65 Danzer E, Gerdes M, Bebbington MW, et al. Lower extremity neuromotor function and short-term ambulatory potential following in utero myelomeningocele surgery. Fetal Diagn Ther. 2009;25(1):47-53. [pmid: 19174610].
66 Bruner JP, Tulipan N, Reed G, et al. Intrauterine repair of spina bifida: preoperative predictors of shunt-dependent hydrocephalus. Am J Obstet Gynecol. 05. 2004;190(5):1305-1312. [pmid: 15167834].
67 Hamdan AH, Walsh W, Heddings A, et al. Gestational age at intrauterine myelomeningocele repair does not influence the risk of prematurity. Fetal Diagn Ther. 03-04. 2002;17(2):66-68. [pmid: 11844907].
68 Mangels KJ, Tulipan N, Bruner JP, et al. Use of bipedicular advancement flaps for intrauterine closure of myeloschisis. Pediatr Neurosurg. 01. 2000;32(1):52-56. [pmid: 10765140].
69 Tulipan N, Hernanz-Schulman M, Lowe LH, et al. Intrauterine myelomeningocele repair reverses preexisting hindbrain herniation. Pediatr Neurosurg. 09. 1999;31(3):137-142. [pmid: 10708355].
70 Tulipan N, Bruner JP. Myelomeningocele repair in utero: a report of three cases. Pediatr Neurosurg. 04. 1998;28(4):177-180. [pmid: 9732243].
71 Tulipan N, Hernanz-Schulman M, Bruner JP. Reduced hindbrain herniation after intrauterine myelomeningocele repair: A report of four cases. Pediatr Neurosurg. 11. 1998;29(5):274-278. [pmid: 9917546].
72 Farmer DL, von Koch CS, Peacock WJ, et al. In utero repair of myelomeningocele: experimental pathophysiology, initial clinical experience, and outcomes. Arch Surg. 08. 2003;138(8):872-878. [pmid: 12912746].
73 Holmes NM, Nguyen HT, Harrison MR, et al. Fetal intervention for myelomeningocele: effect on postnatal bladder function. J Urol. 12. 2001;166(6):2383-2386. [pmid: 11696792].
74 Bruner JP, Richards WO, Tulipan NB, et al. Endoscopic coverage of fetal myelomeningocele in utero. Am J Obstet Gynecol. 01. 1999;180(1 Pt 1):153-158. [pmid: 9914596].
75 Chervenak FA, McCullough LB, Birnbach DJ. Ethical issues in fetal surgery research. Best Pract Res Clin Anaesthesiol. 06. 2004;18(2):221-230. [pmid: 15171501].
76 Golbus MS, Harrison MR, Filly RA. Prenatal diagnosis and treatment of fetal hydronephrosis. Semin Perinatol. 04. 1983;7(2):102-108. [pmid: 6635668].
77 Harrison MR, Golbus MS, Filly RA, et al. Management of the fetus with congenital hydronephrosis. J Pediatr Surg. 12. 1982;17(6):728-742. [pmid: 7161663].
78 Welsh A, Agarwal S, Kumar S, et al. Fetal cystoscopy in the management of fetal obstructive uropathy: experience in a single European centre. Prenat Diagn. 12. 30. 2003;23(13):1033-1041. [pmid: 14691987].
79 Quintero RA, Johnson MP, Romero R, et al. In-utero percutaneous cystoscopy in the management of fetal lower obstructive uropathy. Lancet. 08. 26. 1995;346(8974):537-540. [pmid: 7658779].
80 Johnson MP, Bukowski TP, Reitleman C, et al. In utero surgical treatment of fetal obstructive uropathy: a new comprehensive approach to identify appropriate candidates for vesicoamniotic shunt therapy. Am J Obstet Gynecol. 06. 1994;170(6):1770-1776. discussion 1776–1779. [pmid: 8203438].
81 Salam MA. Posterior urethral valve: Outcome of antenatal intervention. Int J Urol. 10. 2006;13(10):1317-1322. [pmid: 17010011].
82 Wilson RD, Johnson MP. Prenatal ultrasound guided percutaneous shunts for obstructive uropathy and thoracic disease. Semin Pediatr Surg. 08. 2003;12(3):182-189. [pmid: 12961112].
83 Warne S, Chitty LS, Wilcox DT. Prenatal diagnosis of cloacal anomalies. BJU Int. 01. 2002;89(1):78-81. [pmid: 11849166].
84 Holmes N, Harrison MR, Baskin LS. Fetal surgery for posterior urethral valves: long-term postnatal outcomes. Pediatrics. 07. 2001;108(1):E7. [pmid: 11433086].
85 McLorie G, Farhat W, Khoury A, et al. Outcome analysis of vesicoamniotic shunting in a comprehensive population. J Urol. 09. 2001;166(3):1036-1040. [pmid: 11490292].
86 Freedman AL, Bukowski TP, Smith CA, et al. Fetal therapy for obstructive uropathy: diagnosis specific outcomes [corrected]. J Urol. 08. 1996;156(2 Pt 2):720-723. discussion 723–724. [pmid: 8683768].
87 Crombleholme TM, Harrison MR, Golbus MS, et al. Fetal intervention in obstructive uropathy: prognostic indicators and efficacy of intervention. Am J Obstet Gynecol. 05. 1990;162(5):1239-1244. [pmid: 2187354].
88 Araujo Junior E, Guimaraes Filho HA, Saito M, et al. Percutaneous fetal surgery using epidural catheter: preliminary experience acquired from 24 cases. Arch Gynecol Obstet. 07. 2007;276(1):29-33. [pmid: 17492300].
89 Craparo FJ, Rustico M, Tassis B, et al. Fetal serum beta2-microglobulin before and after bladder shunting: a 2-step approach to evaluate fetuses with lower urinary tract obstruction. J Urol. 12. 2007;178(6):2576-2579. [pmid: 17945303].
90 Biard JM, Johnson MP, Carr MC, et al. Long-term outcomes in children treated by prenatal vesicoamniotic shunting for lower urinary tract obstruction. Obstet Gynecol. 09. 2005;106(3):503-508. [pmid: 16135579].
91 Makino Y, Kobayashi H, Kyono K, et al. Clinical results of fetal obstructive uropathy treated by vesicoamniotic shunting. Urology. 01. 2000;55(1):118-122. [pmid: 10654907].
92 Freedman AL, Johnson MP, Smith CA, et al. Long-term outcome in children after antenatal intervention for obstructive uropathies. Lancet. 07. 31. 1999;354(9176):374-377. [pmid: 10437866].
93 Evans MI, Sacks AJ, Johnson MP, et al. Sequential invasive assessment of fetal renal function and the intrauterine treatment of fetal obstructive uropathies. Obstet Gynecol. 04. 1991;77(4):545-550. [pmid: 2002977].
94 Manning FA, Harrison MR, Rodeck C. Catheter shunts for fetal hydronephrosis and hydrocephalus. Report of the International Fetal Surgery Registry. N Engl J Med. 07. 31. 1986;315(5):336-340. [pmid: 3724830].
95 Gehring JE, Cain MP, Casale AJ, et al. Abdominal wall hernia: an uncommon complication of in utero vesicoamniotic shunt placement. Urology. 08. 1. 2000;56(2):330. [pmid: 10925108].
96 Shimada K, Hosokawa S, Tohda A, et al. Follow-up of children after fetal treatment for obstructive uropathy. Int J Urol. 07. 1998;5(4):312-316. [pmid: 9712437].
97 Pinckert TL, Kiernan SC. In utero nephrostomy catheter placement. Fetal Diagn Ther. 09-10. 1994;9(5):348-352. [pmid: 7818785].
98 Bernaschek G, Deutinger J, Hansmann M, et al. Feto-amniotic shunting—report of the experience of four European centres. Prenat Diagn. 09. 1994;14(9):821-833. [pmid: 7845890].
99 Robichaux AG III, Mandell J, Greene MF, et al. Fetal abdominal wall defect: a new complication of vesicoamniotic shunting. Fetal Diagn Ther. 1991;6(1–2):11-13. [pmid: 1837455].
100 Crombleholme TM, Harrison MR, Langer JC, et al. Early experience with open fetal surgery for congenital hydronephrosis. J Pediatr Surg. 12. 1988;23(12):1114-1121. [pmid: 3236176].
101 Manning FA, Harman CR, Lange IR, et al. Antepartum chronic fetal vesicoamniotic shunts for obstructive uropathy: A report of two cases. Am J Obstet Gynecol. 04. 1. 1983;145(7):819-822. [pmid: 6837660].
102 Johnson MP, Corsi P, Bradfield W, et al. Sequential urinalysis improves evaluation of fetal renal function in obstructive uropathy. Am J Obstet Gynecol. 07. 1995;173(1):59-65. [pmid: 7631728].
103 Neubert S, Trautmann K, Tanner B, et al. Sonographic prognostic factors in prenatal diagnosis of SCT. Fetal Diagn Ther. 07-08. 2004;19(4):319-326. [pmid: 15192290].
104 Flake AW. Fetal sacrococcygeal teratoma. Semin Pediatr Surg. 05. 1993;2(2):113-120. [pmid: 8062028].
105 Chisholm CA, Heider AL, Kuller JA, et al. Prenatal diagnosis and perinatal management of fetal sacrococcygeal teratoma. Am J Perinatol. 1999;16(1):47-50. [pmid: 10362082].
106 Uchiyama M, Iwafuchi M, Naitoh M, et al. Sacrococcygeal teratoma: a series of 19 cases with long-term follow-up. Eur J Pediatr Surg. 06. 1999;9(3):158-162. [pmid: 10427491].
107 Schmidt KG, Silverman NH, Harison MR, et al. High-output cardiac failure in fetuses with large sacrococcygeal teratoma: diagnosis by echocardiography and Doppler ultrasound. J Pediatr. 06. 1989;114(6):1023-1028. [pmid: 2656957].
108 Westerburg B, Feldstein VA, Sandberg PL, et al. Sonographic prognostic factors in fetuses with sacrococcygeal teratoma. J Pediatr Surg. 02. 2000;35(2):322-325. discussion 325–326. [pmid: 10693688].
109 Bond SJ, Harrison MR, Schmidt KG, et al. Death due to high-output cardiac failure in fetal sacrococcygeal teratoma. J Pediatr Surg. 12. 1990;25(12):1287-1291. [pmid: 2286911].
110 Grethel EJ, Wagner AJ, Clifton MS, et al. Fetal intervention for mass lesions and hydrops improves outcome: a 15-year experience. J Pediatr Surg. 01. 2007;42(1):117-123. [pmid: 17208551].
111 Danzer E, Hubbard AM, Hedrick HL, et al. Diagnosis and characterization of fetal sacrococcygeal teratoma with prenatal MRI. AJR Am J Roentgenol. 10. 2006;187(4):W350-W356. [pmid: 16985105].
112 Hedrick HL, Flake AW, Crombleholme TM, et al. Sacrococcygeal teratoma: prenatal assessment, fetal intervention, and outcome. J Pediatr Surg. 03. 2004;39(3):430-438. discussion 430–438. [pmid: 15017565].
113 Makin EC, Hyett J, Ade-Ajayi N, et al. Outcome of antenatally diagnosed sacrococcygeal teratomas: single-center experience (1993–2004). J Pediatr Surg. 02. 2006;41(2):388-393. [pmid: 16481257].
114 Paek BW, Jennings RW, Harrison MR, et al. Radiofrequency ablation of human fetal sacrococcygeal teratoma. Am J Obstet Gynecol. 02. 2001;184(3):503-507. [pmid: 11228510].
115 Kay S, Khalife S, Laberge JM, et al. Prenatal percutaneous needle drainage of cystic sacrococcygeal teratomas. J Pediatr Surg. 07. 1999;34(7):1148-1151. [pmid: 10442611].
116 Pumberger W, Hormann M, Deutinger J, et al. Longitudinal observation of antenatally detected congenital lung malformations (CLM): natural history, clinical outcome and long-term follow-up. Eur J Cardiothorac Surg. 11. 2003;24(5):703-711. [pmid: 14583302].
117 Harrison MR, Adzick NS, Jennings RW, et al. Antenatal intervention for congenital cystic adenomatoid malformation. Lancet. 10. 20. 1990;336(8721):965-967. [pmid: 1977005].
118 Dommergues M, Louis-Sylvestre C, Mandelbrot L, et al. Congenital adenomatoid malformation of the lung: when is active fetal therapy indicated?. Am J Obstet Gynecol. 10. 1997;177(4):953-958. [pmid: 9369851].
119 Revillon Y, Jan D, Plattner V, et al. Congenital cystic adenomatoid malformation of the lung: prenatal management and prognosis. J Pediatr Surg. 08. 1993;28(8):1009-1011. [pmid: 8229585].
120 Adzick NS, Harrison MR, Crombleholme TM, et al. Fetal lung lesions: management and outcome. Am J Obstet Gynecol. 10. 1998;179(4):884-889. [pmid: 9790364].
121 Adzick NS. Fetal cystic adenomatoid malformation of the lung: diagnosis, perinatal management, and outcome. Semin Thorac Cardiovasc Surg. 10. 1994;6(4):247-252. [pmid: 7803584].
122 Adzick NS, Harrison MR, Flake AW, et al. Fetal surgery for cystic adenomatoid malformation of the lung. J Pediatr Surg. 06. 1993;28(6):806-812. [pmid: 8331508].
123 Cha I, Adzick NS, Harrison MR, et al. Fetal congenital cystic adenomatoid malformations of the lung: a clinicopathologic study of eleven cases. Am J Surg Pathol. 05. 1997;21(5):537-544. [pmid: 9158677].
124 Kuller JA, Yankowitz J, Goldberg JD, et al. Outcome of antenatally diagnosed cystic adenomatoid malformations. Am J Obstet Gynecol. 10. 1992;167(4 Pt 1):1038-1041. [pmid: 1415388].
125 Merchant AM, Peranteau W, Wilson RD, et al. Postnatal chest wall deformities after fetal thoracoamniotic shunting for congenital cystic adenomatoid malformation. Fetal Diagn Ther. 2007;22(6):435-439. [pmid: 17652932].
126 Morikawa M, Yamada H, Okuyama K, et al. Prenatal diagnosis and fetal therapy of congenital cystic adenomatoid malformation type I of the lung: a report of five cases. Congenit Anom (Kyoto). 03. 2003;43(1):72-78. [pmid: 12692406].
127 Morris LM, Lim FY, Livingston JC, et al. High-risk fetal congenital pulmonary airway malformations have a variable response to steroids. J Pediatr Surg. 01. 2009;44(1):60-65. [pmid: 19159718].
128 Wilson RD, Baxter JK, Johnson MP, et al. Thoracoamniotic shunts: fetal treatment of pleural effusions and congenital cystic adenomatoid malformations. Fetal Diagn Ther. 09-10. 2004;19(5):413-420. [pmid: 15305098].
129 Golaszewski T, Bettelheim D, Eppel W, et al. Cystic adenomatoid malformation of the lung: prenatal diagnosis, prognostic factors and fetal outcome. Gynecol Obstet Invest. 1998;46(4):241-246. [pmid: 9813442].
130 Becmeur F, Donato L, Horta-Geraud P, et al. Pulmonary sequestrations. Pediatr Pulmonol Suppl. 1997;16:129-130. [pmid: 9443238].
131 Bermudez C, Perez-Wulff J, Arcadipane M, et al. Percutaneous fetal sclerotherapy for congenital cystic adenomatoid malformation of the lung. Fetal Diagn Ther. 2008;24(3):237-240. [pmid: 18753764].
132 Johnson A, Moise KJ Jr. Improving survival in twin-twin transfusion syndrome. Contemporary OB/GYN. 2006;51(12):54-59.
133 Martin JA, Hamilton BE, Sutton PD, et al. Births: final data for 2003. Natl Vital Stat Rep. 09. 8. 2005;54(2):1-116.
134 Quintero RA, Morales WJ, Allen MH, et al. Staging of twin-twin transfusion syndrome. J Perinatol. 12. 1999;19(8 Pt 1):550-555. [pmid: 10645517].
135 Baldwin VJ, Wittmann BK. Pathology of intragestational intervention in twin-to-twin transfusion syndrome. Pediatr Pathol. 1990;10(1–2):79-93. [pmid: 2179921].
136 De Lia JE, Cruikshank DP, Keye WR Jr. Fetoscopic neodymium:YAG laser occlusion of placental vessels in severe twin-twin transfusion syndrome. Obstet Gynecol. 06. 1990;75(6):1046-1053. [pmid: 2342732].
137 Chescheir NC. Maternal-Fetal Surgery: Where Are We and How Did We Get Here?. Obstet Gynecol. 2009;113(3):717-731. [pmid: 19300340].
138 Moise KJ Jr, Dorman K, Lamvu G, et al. A randomized trial of amnioreduction versus septostomy in the treatment of twin-twin transfusion syndrome. Am J Obstet Gynecol. 09. 2005;193(3 Pt 1):701-707. [pmid: 16150263].
139 Crombleholme TM, Shera D, Lee H, et al. A prospective, randomized, multicenter trial of amnioreduction vs selective fetoscopic laser photocoagulation for the treatment of severe twin-twin transfusion syndrome. Am J Obstet Gynecol. 10. 2007;197(4):396e.1-396e.9. [pmid: 17904975].
140 Senat MV, Deprest J, Boulvain M, et al. Endoscopic laser surgery versus serial amnioreduction for severe twin-to-twin transfusion syndrome. N Engl J Med. 07. 8. 2004;351(2):136-144. [pmid: 15238624].
141 Chmait RH, Khan A, Benirschke K, et al. Perinatal survival following preferential sequential selective laser surgery for twin-twin transfusion syndrome. J Matern Fetal Neonatal Med. 01. 2010;23(1):10-16. [pmid: 19626566].
142 Chavira ER, Khan A, Korst LM, et al. Are patients with twin-twin transfusion syndrome and a very short cervix candidates for laser surgery?. J Ultrasound Med. 05. 2009;28(5):633-639. [pmid: 19389902].
143 Quintero RA, Ishii K, Chmait RH, et al. Sequential selective laser photocoagulation of communicating vessels in twin-twin transfusion syndrome. J Matern Fetal Neonatal Med. 10. 2007;20(10):763-768. [pmid: 17763279].
144 Gardiner HM, Taylor MJ, Karatza A, et al. Twin-twin transfusion syndrome: the influence of intrauterine laser photocoagulation on arterial distensibility in childhood. Circulation. 04. 15. 2003;107(14):1906-1911. [pmid: 12665487].
145 Habli M, Livingston J, Harmon J, et al. The outcome of twin-twin transfusion syndrome complicated with placental insufficiency. Am J Obstet Gynecol. 10. 2008;199(4):424e.1-424e.6. [pmid: 18928994].
146 Lenclen R, Paupe A, Ciarlo G, et al. Neonatal outcome in preterm monochorionic twins with twin-to-twin transfusion syndrome after intrauterine treatment with amnioreduction or fetoscopic laser surgery: comparison with dichorionic twins. Am J Obstet Gynecol. 05. 2007;196(5):450e.1-450e.7. [pmid: 17466697].
147 Lenclen R, Ciarlo G, Paupe A, et al. Neurodevelopmental outcome at 2 years in children born preterm treated by amnioreduction or fetoscopic laser surgery for twin-to-twin transfusion syndrome: comparison with dichorionic twins. Am J Obstet Gynecol. 09. 2009;201(3):291e.1-291e.5. [pmid: 19608152].
148 Middeldorp JM, Lopriore E, Sueters M, et al. Twin-to-twin transfusion syndrome after 26 weeks of gestation: is there a role for fetoscopic laser surgery?. BJOG. 06. 2007;114(6):694-698. [pmid: 17516960].
149 Wagner MM, Lopriore E, Klumper FJ, et al. Short- and long-term outcome in stage 1 twin-to-twin transfusion syndrome treated with laser surgery compared with conservative management. Am J Obstet Gynecol. 09. 2009;201(3):286e.1-286e.6. [pmid: 19628199].
150 Santiago JC, Ramos-Corpas DJ, Castillo MJ. Endoscopic laser surgery after therapeutic amniocentesis in the treatment of severe twin–twin transfusion syndrome. Int J Gynaecol Obstet. 03. 2006;92(3):262-263. [pmid: 16434040].
151 Quintero RA, Dickinson JE, Morales WJ, et al. Stage-based treatment of twin-twin transfusion syndrome. Am J Obstet Gynecol. 05. 2003;188(5):1333-1340. [pmid: 12748508].
152 Quintero RA, Comas C, Bornick PW, et al. Selective versus non-selective laser photocoagulation of placental vessels in twin-to-twin transfusion syndrome. Ultrasound Obstet Gynecol. 09. 2000;16(3):230-236. [pmid: 11169288].
153 Habli M, Bombrys A, Lewis D, et al. Incidence of complications in twin-twin transfusion syndrome after selective fetoscopic laser photocoagulation: a single-center experience. Am J Obstet Gynecol. 10. 2009;201(4):417e.1-417e.7. [pmid: 19788973].
154 Chang J, Tracy TF Jr, Carr SR, et al. Port insertion and removal techniques to minimize premature rupture of the membranes in endoscopic fetal surgery. J Pediatr Surg. 05. 2006;41(5):905-909. [pmid: 16677880].
155 Yamamoto M, El Murr L, Robyr R, et al. Incidence and impact of perioperative complications in 175 fetoscopy-guided laser coagulations of chorionic plate anastomoses in fetofetal transfusion syndrome before 26 weeks of gestation. Am J Obstet Gynecol. 09. 2005;193(3 Pt 2):1110-1116. [pmid: 16157121].
156 Lopriore E, Middeldorp JM, Sueters M, et al. Long-term neurodevelopmental outcome in twin-to-twin transfusion syndrome treated with fetoscopic laser surgery. Am J Obstet Gynecol. 03. 2007;196(3):231 e1-e4. [pmid: 17346532].
157 Moise KJ Jr, Johnson A, Carpenter RJ, et al. Fetal intervention: providing reasonable access to quality care. Obstet Gynecol. 02. 2009;113(2 Pt 1):408-410. [pmid: 19155914].
158 Chescheir NC, Socol M. The National Institutes of Health Workshop on Fetal Treatment: needs assessment and future directions. Obstet Gynecol. 10. 2005;106(4):828-833. [pmid: 16199643].
159 Wilson RD, Johnson MP, Flake AW, et al. Reproductive outcomes after pregnancy complicated by maternal-fetal surgery. Am J Obstet Gynecol. 10. 2004;191(4):1430-1436. [pmid: 15507978].
160 Farrell JA, Albanese CT, Jennings RW, et al. Maternal fertility is not affected by fetal surgery. Fetal Diagn Ther. 05-06. 1999;14(3):190-192. [pmid: 10364673].
161 Longaker MT, Golbus MS, Filly RA, et al. Maternal outcome after open fetal surgery. A review of the first 17 human cases. JAMA. 02. 13. 1991;265(6):737-741. [pmid: 1990189].
162 Golombeck K, Ball RH, Lee H, et al. Maternal morbidity after maternal-fetal surgery. Am J Obstet Gynecol. 03. 2006;194(3):834-839. [pmid: 16522421].
163 Harrison MR. Fetal surgery: trials, tribulations, and turf. J Pediatr Surg. 03. 2003;38(3):275-282. [pmid: 12632335].