# Methods

## Overview

This brief combined standard systematic review approaches with Internet searches and key informant discussions.

## Search Strategy

Search of the literature. We began our scan of the literature with a broad, general search query including key Medical Subject Heading (MeSH) terms and keywords related to fetal surgical procedures. The variability in subject term indexing among the retrieved citations in PubMed led to the development of additional search strategies to increase the comprehensiveness of our search retrieval.

From the combined retrieval of each of these search sets, we excluded publications that lay beyond the scope of the technical brief (letters, comments, editorials, reviews, news, practice guidelines), focusing on retaining items comprising primary data (case reports, prospective and retrospective studies).

We searched the Internet extensively to identify locations in the United States offering maternal-fetal surgical procedures; we also searched for insurance policies related to fetal interventions for a selected set of insurers. Searches were conducted across a number of fetal medicine-related Web sites as well as commercial databases including LexisNexis and ProQuest. We searched databases including Clinicaltrials.gov to identify current research. Appendix A includes further information about our search strategies and results.

## Eligibility Criteria

Our inclusion/exclusion criteria for the research literature are shown in Table 1. All titles and abstracts identified through searches against our inclusion/exclusion criteria were reviewed by at least two investigators. When differences between the reviewers arose, we erred on the side of inclusion. For studies without adequate information to make the determination, we retrieved the full-text articles and reviewed them against the inclusion/exclusion criteria.

Table 1 Inclusion/exclusion criteria

Category | Criteria
Study population | Women and their fetuses with documented abnormalities on ultrasound that would require surgical correction
Publication languages | English only
Admissible evidence (study design and other criteria) | [underlined: Admissible designs] Randomized controlled trials, cohorts with comparison, case-control and case series with n ≥ 2 [underlined: Other criteria]; - Original research studies that provide sufficient detail regarding methods and results to enable use and adjustment of the data and results; - Studies must address one or more of the following for fetal procedures:; - Treatment modality; - Current medical practice of training; - Short- and long-term outcomes, including maternal morbidity and mortality

We collected data from the studies to provide an overview of the status of research in the field by collecting the following information:

- Study design, country, and setting
- Research methods
- Type of procedure
- Fetal and maternal inclusion criteria
- Training of providers/specialized expertise and equipment in the study hospital
- Comparator used in comparative studies
- Length of followup
- Fetal and maternal outcomes measured
- Adverse events/harms/safety issues

## Expert Panel Discussions

We consulted with experts selected because of their expertise in the following areas: expertise in each of the conditions of interest, those who could offer historical perspective on maternal-fetal surgical procedures, and individuals who had a particular subspecialty expertise, such as ethics. These three panels included a total of 17 experts with whom we held conversations via phone, lasting from 20 to 45 minutes. The conversations were unstructured and intended to elicit context and background related in particular to current practice of maternal-fetal surgery.

## Describing the State of the Science

In text and tables through the report, we aimed to use counts to effectively describe the status of the available science on maternal-fetal surgical intervention. When possible, studies that include common participants from a single site are grouped together, and groupings are indicated. We recognize that duplications of individual mother-baby pairs nonetheless occur in the total counts. The total number of cases studied is certain to be lower than totals in tables reflect. Our tables provide information that exceeds that in the text, and taken together within a section, they are the best source of a single view of the quality and strength of the evidence by topic.