# Discussion

## State of the Science

The crosscutting focus of this review is summarizing the state of the field of maternal-fetal surgical procedures, broadly defined to include topics such as training of providers, access to care, and strength of the research literature for understanding the anticipated effectiveness of fetal approaches in practice. Stakeholders requesting the report were specifically interested in instances in which strong comparative research suggests superiority of maternal-fetal surgical procedures over intervention at birth for reducing fetal, intrapartum, and neonatal mortality and for preserving organ function. However in compiling this literature it is apparent that, while developing rapidly, the research on fetal surgical procedures has not achieved the typical level of quality of studies and aggregate strength of the evidence used to reach definitive conclusions about care and policy.

Favorable signs include the substantive leadership of U.S. researchers across each of the topics considered. For each target condition, there are both fetal surgical centers and associated research enterprises engaged in the full spectrum of academic endeavor, from animal research, development of surgical interventions, and refinements, to patient care, surgical training, bioethics forums, and reporting of results in the scientific literature. The majority of fetal surgical innovations arose in the United States, and the momentum of the literatures suggest continued growth of expertise alongside a commitment to assuring forthright examination of the outcomes of maternal-fetal surgical care. All publications across both the United States and internationally reflected the involvement of tertiary care academic medical centers, and scholarly work is clearly woven into the fabric of maternal-fetal surgery care. Thus, available data are likely to be relevant to care and trends in the United States.

Randomized trials, a total of three published in two topics (CDH and TTTS), are rare. Experts and authors in this area rightly point out both the desirability of randomized trials and the factors that mitigate success of trials, including small numbers of fetuses with specific conditions, need for methodologic advancement for study of this topic, patients who span the country while academic research centers are sparsely distributed, insufficient mechanisms to absorb the costs of care for participants who are participating in research, lack of national research infrastructure to coordinate trials, and in some instances, competing availability of procedures outside the trial.157–158 When conducted, the results have had influence in redirecting the field. The finding that open fetal repair of CDH did not improve outcomes compared to repair at birth, helped focus continued development of interventions on less invasive approaches that now include comparison of approaches for balloon tracheal occlusion. Trials suggesting superiority of laser ablation of vessels to serial amnioreduction also refocused the field on comparisons of less invasive approaches.

Prospective studies, with the potential to standardize protocols and elements of data collection and outcome measurement, are also few. Eleven of 166 total study populations (7 percent) were classified as prospective cohorts for this count. We erred on the side of inclusiveness, counting all use of research registries that prospectively capture individual case data, whether local or multisite, as prospective data collection. Retrospective cohorts, a total of 36, made up 22 percent of the total study populations reported in the literature. Retrospective studies were less likely to compare to fetal interventions and most likely to have historical comparison groups.

Cohort studies have fundamental challenges with comparability of the comparison group because the decision to act or defer intervention until the postnatal timeframe is often entangled with clinically assessed prognosis. Infants who were expected to do well without intervention would be less likely to have fetal surgery and would potentially do better than those who received fetal surgery. Conversely, those who were felt to have grim survivability are often noted to have been offered termination or to have had treatment withheld secondary to perceived futility. The latter scenario overestimates the benefit of fetal intervention compared to those with extremely poor prognosis. The number of cases with similar characteristics between those who received surgery and those who did not accept referral to procedures is rarely reported. The total number in the literature is insufficient to make estimates that are legitimately comparable. Furthermore, data collection is often imbalanced, with greater detail available for the cases that underwent surgery than those that did not.

Few cohort studies were large and thorough enough to conduct appropriately powered multivariable analysis to adjust for candidate confounders or modifiers of treatment outcomes. TTTS was the exception, and findings from this area, which reflect greater numbers of pregnancies in individual studies available to aggregate, are more secure. Consensus is developing that vascular ablation procedures are superior to serial amnioreduction, and attention has turned to evaluating selective versus nonselective approaches to targeting vessels. For the majority of the conditions of interest, aggregating the number of participants would still fall short of that needed for metaregression, and key confounders and modifiers of outcomes appear not to be available uniformly across research groups.

Case series dominate the maternal-fetal surgical procedures literature, making up 70 percent of the included studies. This dominance of descriptive work is not an indictment, rather a natural consequence of the arrival of the fetus as a surgical candidate within the last 3 decades.

As expected, the literature for each type of approach reflects initial case reports of technical aspects of the surgery, followed by publications about selection criteria, then prognostics, and then conversion to including a comparison group and transitioning to cohort analyses. Increments of followup lengthen and the status of early cases is typically updated beyond infancy into childhood in later publications. This natural evolution of the field shows in the trend toward rising numbers cohort and prospective studies as we approach contemporary timeframes.

The strength of protocol-based research lies in gathering comparable information across an entire study population. The opportunity to use standardized timing of assessment, similar lengths of followup for those included in the analysis, or validated assessment tools for evaluation of characteristics such as neonatal and childhood developmental status is not yet being optimized. Twenty-eight percent of the publications report outcomes to birth only, and followup into childhood is meager. Outcomes of crucial interest such as neurodevelopmental status and quality of life for children and their families are rarely reported (Table 17). Complications of prematurity, a frequent sequelae of maternal-fetal surgical procedures or the conditions themselves, are not well reported. Surprisingly, gaps also exist in the reporting of the functional status of the target organ for which the procedure was done (i.e. need for renal transplant among infants with vesicoamniotic shunt placement).

Table 17 Counts of studies reporting outcomes of maternal-fetal surgical procedures

Procedure (total number of studies) | Fetal and Infant | | | | | | Maternal
Procedure (total number of studies) | Survival to birth | Preterm birth | Neonatal deaths | Pulmonary status | Neonatal neurologic status | Developmental status in infancy or childhood | Mortality or intensive care | Infections and wound healing complications | Length of stay | Uterine rupture (index or later pregnancy) | Subsequent fertility or reproductive outcomes
Cardiac malformations
Atrial septoplasty (3) | 3 | 2 | 3
Aortic valvuloplasty (8) | 5 | 5 | 5 | | | | 4 | 3
Pulmonary valvuloplasty (2) | 1 | 1 | 1
Congenital diaphragmatic hernia
Hysterotomy (8) | 6 | 6 | 6 | -- | 4 | 4 | 4 | 4 | 3 | 2 | 2
Laparoscopic (12) | 10 | 10 | 10 | -- | 2 | 3 | 4 | 4 | 2 | 2 | 1
Percutaneous (6) | 6 | 6 | 6 | -- | | | 3 | 2 | 1
Myelomeningocele
Hysterotomy (9) | 6 | 7 | 6 | -- | 7 | 3 | 4 | 1 | | 1
Obstructive uropathy
Vesicoamniotic or other shunt (24) | 24 | 23 | 24 | 10 | 1 | 5 | | 1
Hysterotomy with repair (3) | 3 | 3 | 3 | 2 | | | | 1 | | | 1
Sacrococcygeal teratoma
Hysterotomy (3) | 3 | 3 | 3 | | | | 1 | 1
Laparoscopic (1) | 1 | 1 | 1
Percutaneous (5) | 4 | 4 | 4 | | | | 2 | 1
Thoracic lesions
Thoracoamniotic shunt (9) | 8 | 6 | 8 | -- | 1 | 1
Open resection (3) | 3 | 2 | 3 | -- | 1 | 1 | 1
Twin-twin transfusion syndrome
Laser ablation (84) | 67 | 61 | 48 | 1 | 19 | 13 | 4 | 10

NOTE: This table summarizes whether or not the publications considered these key outcomes, not the number of outcomes themselves. Some publications include more than one intervention and are counted under each intervention.

Other notable gaps include sparse information about anesthesia care, intra-operative monitoring of mother and fetus, postoperative care, and specialized nursing considerations. Near-absence of maternal outcome assessment, including a significant lack of data on future maternal reproductive health, is especially concerning.159–161 The single publication that examined maternal outcomes across the spectrum of maternal-fetal surgical procedures for 187 women, reported 26 percent of women having open fetal procedures had an intensive care stay and 2.3 percent were intubated.162 The team found across open, endoscopic, and percutaneous approaches combined that preterm labor resulting in birth affected 27 percent of pregnancies and preterm premature rupture of membranes 44 percent, with cesarean birth being the route of delivery for 70 percent. These and other details, such as the fact that 29 percent of women remained hospitalized until birth, are crucial to providing comprehensive anticipatory guidance during the process of informed decisionmaking about maternal-fetal surgical procedures.

Despite these weaknesses, the overall momentum is toward more robust research and rigorous, more consistent documentation of outcomes over longer periods of time. All three trials were conducted in the last decade, and each decade since the 1980s, the number of cohort studies has increased, with a threefold increase between 33 cohorts in the 2000s compared to 11 in the 1990s. Experts concurred in discussions as well as in the literature that they are eager to develop consensus measures as well as mechanisms to make implementation of common protocols and larger studies, both trials and prospective cohorts, increasingly possible.

The field is also benefitting from the contributions of groups like International Fetal Medicine and Surgery Society, the North American Fetal Therapy Network, and the International Fetal Surgery Registry. Large-scale collaborations promote not only aggregation of more participants but also standardization of measures, extended duration of followup, and emphasis on multisite trial research prioritization. Ongoing trials such as the National Institutes of Health Management of Myelomeningocele Study (MOMS) have also had beneficial effects on promoting strategies that enhance feasibility of study of rare conditions, such as commitments to provide the procedure under study only within trials and coordinating regional access.

## Challenges and Opportunities

Fetal surgery teams, related research groups, professional associations, government agencies, and individual consumers with an affected fetus have a vested interest in the continued growth and sophistication of the study of outcomes of maternal-fetal surgical procedures. A number of challenges are presented, both individually and in combination:

- Relative rareness of specific anomalies, with no regional or national method to identify or consolidate new cases to be offered protocol involvement
- Need to accumulate cases over long periods of time, during which changes in other aspects of care such as innovations in neonatal care or pediatric surgery can change the benefit equation for fetal intervention or during which new surgical tools are introduced
- Variation in clinical care and research classifications of fetal anomalies and in accuracy of antenatal diagnosis, with limited diagnostic accuracy literature to draw on that reflects the general population of pregnant women in the United States
- Observation in some conditions that spontaneous regression or stabilization occurs
- Less than full agreement between staging or severity assessment systems and outcomes indicating prognosis is at present not fully discoverable from clinical assessments
- Changes in the spectrum of disease, to include previously undetected and possibly less severe cases, as imaging becomes more and more advanced with the result of reducing comparability to prior natural history studies of anticipated outcomes
- Continuing evolution of in utero interventions, which can complicate comparisons among interventions and outcomes
- Overrepresentation of higher socioeconomic status patients who have some or partial coverage for costs and may not have generalizable risks or outcomes compared to expected population-level outcomes
- Need for a strong assessment of models of care, including the potential for regionalization of care
- Training programs for the next generation of maternal-fetal surgeons, including assessment of whether formal training programs, accreditation or certification are appropriate

Strategies to reduce evidence gaps include:

- Continued development of consensus on operational definitions to uniformly classify and describe severity of conditions
- Enhanced attention to collection of common data elements using uniform approaches, especially for measurement of strong predictors of outcome and for the outcomes themselves
- Use of valid and reliable tools, common in pediatric and developmental biology research, to more globally assess infant and child health status with the long-term goal of ultimately having followup into young adulthood and later to include functional status and quality of life measures
- Cooperative data sharing with these common data elements to include plans for assessing issues of diagnostic accuracy, changing natural history, and prognosis, as well as large-scale multivariable data analysis comparing outcomes
- Use of such analyses to inform the conduct of the most pressing clinical trials in which there is scientific equipoise
- Investment in research infrastructure, external to any one site, that can facilitate achieving these aims
- New methods for funding and sharing cost and liability risk for the conduct of maternal-fetal treatment research
- Establishment of an accepted and consistent set of ethical standards for conduct of research in maternal-fetal procedures

In our discussions with experts across the country, they universally discussed the need for a considered approach to the potential for regionalized care, the need for appropriate and rigorous training, the potential for a move toward a nationally accredited field, and the desire to continue to push the science forward with as much rigor and ethical practice as possible. The coherence of the overall agenda 157–158, 163 and the determination of those with a stake in understanding fetal surgical procedures are strong assurances that the scientific community will continue to build knowledge to inform care when infrastructure and consensus needs are overcome.